# References

1 Ruben RJ Effectiveness and efficacy of early detection of hearing impairment in children Acta Otolaryngol 1991 482(Suppl.):127 31
2 Rach GH, Zielhuis GA, van den Broek P. The influence of chronic persistent otitis media with effusion on language development of 2- to 4- year-olds. Int J Pediatr Otorhinolaryngol. 1988;15:253-61. [pmid: 3192363].
3 Zinkus PW, Gottlieb MI Patterns of Perceptual and Academic Deficits Related to Early Chronic Otitis Media Pediatrics 1980 66(2):2 246
4 Moeller MP, Osberger MJ, Eccarius M. Receptive language skills. Language and Learning Skills of Hearing-Impaired Children. 1986:p. 41-53.
5 Carney AE, Moeller MP Treatment efficacy: hearing loss in children J Speech Lang Hear Res 1998 41(1):S61 84 9493747
6 National Institutes of Health. Early identification of hearing impairment in infants and younger children. Rockville, Maryland; 1993.
7 Fonseca S, Forsyth H, Grigor J, Lowe J, MacKinnon M, Price E, et al Identification of permanent hearing loss in children: are the targets for outcome measures attainable? Br J Audiol 1999 33(3):3 135
8 Davis A, Bamford J, Wilson I, Ramkalawan T, Forshaw M, Wright S A critical review of the role of neonatal hearing screening in the detection of congenital hearing impairment Health Technol Assess 1997 1(10):i iv, 1-176 9483157
9 Meadow-Orlans KP, Mertens DM, Sass-Lehrer MA, Scott-Olson K Support services for parents and their children who are deaf or hard of hearing: a national survey Am Ann Deaf 1997 142(4):4 278
10 Harrison M, Roush J Age of suspicion, identification, and intervention for infants and young children with hearing loss: a national study Ear Hear 1996 17(1):1 55 8741962
11 Kuhl PK, Williams KA, Lacerda F, Stephens KN, Lindbloom B. Linguistic experience alters phonetics perception in infants by six months of age. Science. 1992;255:606-08. [pmid: 1736364].
12 Gopnik A, A. M, Kuhl PK. The scientist in the crib: Minds, brains, and how children learn. New York: William Morrow and Company; 1999.
13 Sininger YS, Doyle KJ, Moore JK The case for early identification of hearing loss in children. Auditory system development, experimental auditory deprivation, and development of speech perception and hearing Pediatr Clin North Am 1999 46(1):1 1 10079786
14 Vohr BR, Carty LM, Moore PE, Letourneau K The Rhode Island Hearing Assessment Program: experience with statewide hearing screening (1993-1996) J Pediatr 1998 133(3):3 353 9672501
15 Finitzo T, Diefendorf AO The state of the information... evidence gathering in infant hearing programs Am J Audiol 1997 6(3):3 91
16 White KR, Vohr BR, Behrens TR Universal newborn hearing screening using transient evoked otoacoustic emissions: results of the Rhode Island haring Assessment Project Semin Hear 1993 14(1):1 18
17 Joint Committee on Infant Hearing Joint committee on infant hearing year 2000 position statement: principles and guidelines for early hearing detection and intervention programs Pediatrics 2000 106(4)798 817 11015525
18 Fortnum H, Davis A Epidemiology of permanent childhood hearing impairment in Trent Region, 1985-1993 Br J Audiol 1997 31(6):6 409
19 U.S. Preventive Services Task Force. Screening for hearing impairment. In: U.S. Preventive Services Task Force. Guide to Clinical Preventive Services. 2nd edition. Washington, DC: Office of Disease Prevention and Health Promotion; 1996. 393-405. [pmcid: 387643].
20 Grandori F, Lutman ME. European Consensus Statement on Neonatal Hearing Screening. Finalised at the European Consensus Development Conference on Neonatal Hearing Screening, 15-16 May 1998, Milan. Int J Pediatr Otorhinolaryngol. 1998;44:309-10. [pmid: 9780076].
21 Stein LK Factors influencing the efficacy of universal newborn hearing screening Pediatr Clin North Am 1999 46(1):1 95 10079786
22 Maki-Torkko EM, Lindholm PK, Vayrynen MRH, Leisti JT, Sorri MJ Epidemiology of moderate to profound childhood hearing impairments in northern Finland. Any changes in ten years? Scand Audiol 1998 27(2):2 95
23 Karikoski JO, Marttila TI Prevalence of childhood hearing impairment in southern Finland Scand Audiol 1995 24(4):4 237
24 Parving A, Jensen JH Prevalence of permanent childhood hearing impairment -- its role in audit of local paediatric hearing health services J Audiol Med 1998 7(2):2 100
25 Boyle CA, Yeargin-Allsopp M, Doernberg NS, Holmgreen MS, Murphy CC, Schendel DE Prevalence of selected developmental disabilities in children 3-10 years of age: the metropolitan Atlanta developmental disabilities surveillance program, 1991 MMWR, CDC Surveillance Summaries 1996 45(SS-2):1 14
26 Van Naarden K, Decoufle P, Caldwell K. Prevalence and Characteristics of Children with Serious Hearing Impairment in Metropolitan Atlanta, 1991-1993. Pediatrics. 1999:p. 570-75.
27 Yoshinaga-Itano C, Apuzzo ML The development of deaf and hard of hearing children identified early through the high-risk registry Am Ann Deaf 1998 143(5):5 416 9557327
28 Karchmer MA, Allen TE The functional assessment of deaf and hard of hearing students Am Ann Deaf 1999 144(2):68 77 10369003
29 Holt JA. Stanford Achievement Test-8th edition;: reading comprehension subgroup results. Am Ann Deaf Ref Iss. 1993;138:172-75.
30 Allen TE. Patterns of academic achievement among hearing impaired students: 1974 and 1983. Deaf Children in America. 1986:161-206.
31 Quigley SO. Environment and communication in the language development of deaf children. In: Bradford LJ, Hardy WG, editors. Hearing and hearing impairment. New York, NY: Grune and Stratton; 1979.
32 Wrightstone JW, Aronow MS, Moskowitz S. Developing reading test norms for deaf children. Am Ann Deaf. 1963;108:311-16.
33 Furth HG. A comparison of reading test norms of deaf and hearing children. Am Ann Deaf. 1966;111:461-2. [pmid: 5931107].
34 Gravel JS, Wallace IF, Ruben RJ Auditory consequences of early mild hearing loss associated with otitis media Acta Otolaryngol 1996 116(2):2 219
35 Bess FH, Dodd-Murphy J, Parker RA Children with minimal sensorineural hearing loss: prevalence, educational performance, and functional status Ear Hear 1998 19(5):339 54 9796643
36 Tharpe AM, Bess FH Minimal, progressive, and fluctuating haring losses in children: Characteristics, identification, and managment Pediatr Clin North Am 1999 46(1):1 65 10079786
37 Dirckx JJ, Daemers K, Somers T, Offeciers FE, Govaerts PJ Numerical assessment of TOAE screening results: currently used criteria and their effect on TOAE prevalence figures Acta Otolaryngol 1996 Sep 116(5):672 9 8908242
38 Fowler KB, McCollister FP, Dahle AJ, Boppana S, Britt WJ, Pass RF Progressive and fluctuating sensorineural hearing loss in children with asymptomatic congenital cytomegalovirus infection J Pediatr 1997 130(4):4 624
39 Lasky RE, Wiorek L, Becker TR Hearing loss in survivors of neonatal extracorporeal membrane oxygenation (ECMO) therapy and high-frequency oscillatory (HFO) therapy J Am Acad Audiol 1998 9(1):1 47 9493937
40 Prieve BA, Stevens F The New York State universal newborn hearing screening demonstration project: introduction and overview Ear Hear 2000 21(2):2 85
41 Widen JE, Folsom RC, Cone-Wesson B, Carty L, Dunnell JJ, Koebsell K, et al Identification of neonatal hearing impairment: hearing status at 8 to 12 months corrected age using a visual reinforcement audiometry protocol Ear Hear 2000 21(5):5 471 10708068
42 Moore JM, Thompson G, Folsom RC. Auditory responsiveness of premature infants utilizing visual reinforcement audiometry (VRA). Ear Hear. 1992;13:187-94. [pmid: 1397759].
43 Folsom RC, Diefendorf AO Physiologic and behavioral approaches to pediatric hearing assessment Pediatr Clin North Am 1999 46(1):1 107 10079786
44 Stredler-Brown A, Arehart KH. Universal newborn hearing screening: impact on early intervention services. Volta Review In Press.
45 Grandori F, Lutman M. The European Consensus Development Conference on Neonatal Hearing Screening (Milan, May 15-16, 1998). Am J Audiol. 1999;8:19-20. [pmid: 10499114].
46 Brookhouser PE Sensorineural hearing loss in children. [Review] Pediatr Clin North Am 1996 43(6):6 1195
47 Eilers RE, Berlin C Advances in early detection of hearing loss in infants Curr Probl Pediatr 1995 25(2):2 60
48 Finitzo T, Crumley WG The role of the pediatrician in hearing loss. From detection to connection. [Review] Pediatr Clin North Am 1999 46(1):15 34, ix-x 10079787
49 Martin WH, Schwegler JW, Gleeson AL, Shi YB New techniques of hearing assessment. [Review] Otolaryngol Clin North Am 1994 27(3):3 487
50 Oudesluys-Murphy AM, van Straaten HL, Bholasingh R, van Zanten GA Neonatal hearing screening. [Review] Eur J Pediatr 1996 155(6):6 429
51 Silverman CA Audiologic assessment and amplification Prim Care 1998 25(3):3 545
52 White KR, Maxon AB. Early identification of hearing loss: implementing universal newborn hearing screening programs. Logan, UT: National Center for Hearing Assessment and Management (NCHAM).
53 Erenberg A, Lemons J, Sia C, Trunkel D, Ziring P Newborn and infant hearing loss: detection and intervention.American Academy of Pediatrics. Task Force on Newborn and Infant Hearing, 1998- 1999 Pediatrics 1999 103(2):2 527
54 Robinshaw HM Acquisition of speech, pre- and post-cochlear implantation: longitudinal studies of a congenitally deaf infant Eur J Disord Commun 1996 31(2):2 121
55 Robinshaw HM The pattern of development from non-communicative behaviour to language by hearing impaired and hearing infants Br J Audiol 1996 30(3):3 177 8839361
56 Robinshaw HM Early intervention for hearing impairment: differences in the timing of communicative and linguistic development Br J Audiol 1995 29(6):6 315
57 White SJ, White REC. The effects of hearing status of the family and age of intervention on receptive and expressive oral language skills in hearing-impaired infants. Development of Language and Communication Skills in Hearing-impaired Children. p. 9-24.
58 Watkins S. Long term effects of home intervention with hearing-impaired children. Am Ann Deaf. 1987;132:267-71. [pmid: 3442286].
59 Musselman CR, Wilson AK, Lindsay PH Effects of early intervention on hearing impaired children Exceptional Children 1988 55(3):3 222
60 Skinner MW The hearing of speech during language acquisition Otolaryngol Clin North Am 1978 11(3):631 50 733250
61 McFarland W, H., Simmons FB The importance of early intervention with severe childhood deafness Pediatr Ann 1980 9(1):13 19 7367046
62 Yoshinaga-Itano C, Sedey AL. Speech development of deaf and hared-of-hearing children in early childhood: inter-relationships with language and hearing. Volta Review In Press.
63 Abrams MJ, Pensak ML, Buhrer K Perspectives on a state enacted hearing screening assessment program in the newborn population Am J Otol 1997 May 18(3):368 72 9149833
64 Apostolopoulos NK, Psarommatis IM, Tsakanikos MD, Dellagrammatikas HD, Douniadakis DE Otoacoustic emission-based hearing screening of a Greek NICU population Int J Pediatr Otorhinolaryngol 1999 47(1):1 41 10206389
65 Chen SJ, Yang EY, Kwan ML, Chang P, Shiao AS, Lien CF Infant hearing screening with an automated auditory brainstem response screener and the auditory brainstem response Acta Paediatr 1996 85(1):1 14 8834970
66 Comerford DG, Watson C, Khan MS, Hussain SS The Bradford and Airedale baby hearing project. An assessment of the impact of screening on the earlier detection of infant hearing loss Clinical Otolaryngology & Allied Sciences 1995 20(6):6 536
67 Elmy HAE, Jurkovicova J, Aghova L Methodical possibilities of early hearing screening in prevention of hearing loss Studia Psychologica 1994 36(5):5 369
68 Hunter MF, Kimm L, Cafarlli Dees D, Kennedy CR, Thornton AR Feasibility of otoacoustic emission detection followed by ABR as a universal neonatal screening test for hearing impairment Br J Audiol 1994 28(1):1 47 7987267
69 Daemers K, Drickx JD, Van Driessche K, Somers T, Offeciers FE, Govaerts PJ Neonatal hearing screening with otoacoustic emissions: an evaluation Acta Otorhinolaryngol Belg 1996 50(3):3 203
70 Lutman ME, Davis AC, Fortnum HM, Wood S Field sensitivity of targeted neonatal hearing screening by transient-evoked otoacoustic emissions Ear Hear 1997 18(4):4 265
71 Mason JA, Herrmann KR. Universal infant hearing screening by automated auditory brainstem response measurement. Pediatrics. 1998;101:221-28. [pmid: 9445495].
72 Oudesluys-Murphy AM, Harlaar J Neonatal hearing screening with an automated auditory brainstem response screener in the infant's home Acta Paediatr 1997 86(6):6 651 9116428
73 Sorenson P Universal hearing screening in the NICU: the Loma Linda University Children's Hospital experience Neonatal Network - Journal of Neonatal Nursing 1998 17(7):7 43
74 Stewart DL, Pearlman A Newborn hearing screening J Ky Med Assoc 1994 92(11):11 444
75 Sutton GJ, Scanlon PE Health visitor screening versus vigilance: outcomes of programmes for detecting permanent childhood hearing loss in West Berkshire Br J Audiol 1999 33(3):3 145
76 Meyer C, Witte J, Hildmann A, Hennecke KH, Schunck KU, Maul K, et al Neonatal screening for hearing disorders in infants at risk: incidence, risk factors, and follow-up Pediatrics 1999 104(4 Pt 1):900 4 10506232
77 1987. [pmcid: 442456].
78 Prieve B, Dalzell L, Berg A, Bradley M, Cacace A The New York State universal newborn hearing screening demonstration project: outpatient outcome measures Ear Hear 2000 21(2):131 40 10777020
79 Controlled trial of universal neonatal screening for early identification of permanent childhood hearing impairment. Wessex Universal Neonatal Hearing Screening Trial Group. Lancet. 1998;352:1957-64. [pmid: 9872244].
80 Finitzo T, Albright K, O'Neal J The Newborn with Hearing Loss: Dectection in the Nursery Pediatrics 1998 102(6):6 1452 9651406
81 Mehl A, Thomson V. Newborn hearing screening: the great omission. Pediatrics. 1998;E4.
82 Barsky-Firkser L, Sun S Universal newborn hearing screenings: a three-year experience Pediatrics 1997 99(6):
83 Watkin PM Outcomes of neonatal screening for hearing loss by otoacoustic emission Arch Dis Child Fetal Neonatal Ed 1996 75(3):F158 68 8976680
84 Aidan D, Avan P, Bonfils P Auditory screening in neonates by means of transient evoked otoacoustic emissions: a report of 2,842 recordings Ann Otol Rhinol Laryngol 1999 Jun 108(6):525 31 10378518
85 Clemens CJ, Davis SA, Bailey AR The “false positive” in universal newborn hearing screening Pediatrics 2000 106(1):10878176
86 Eddy DM. Common Screening Tests. Philadelphia: American College of Physicians; 1991.
87 Yoshinaga-Itano C, Coulter D, Thomson V The Colorado Newborn Hearing Screening Project: effects on speech and language development for children with hearing loss J Perinatol 2000 20(8 Pt 2):S132 7 11190694
88 Yoshinaga-Itano C, Sedey AL, Coulter DK, Mehl AL Language of early- and later-identified children with hearing loss Pediatrics 1998 102(5):5 1161
89 Yoshinaga-Itano C, Apuzzo ML Identification of hearing loss after age 18 months is not early enough Am Ann Deaf 1998 143(5):5 380 9557327
90 Apuzzo M-rL, Yoshinaga-Itano C Early identification of infants with significant hearing loss and the Minnesota child development inventory Semin Hear 1995 16(2):2 124
91 Moeller MP Early intervention and language development in children who are deaf and hard of hearing Pediatrics 2000 106(3):10969127
92 Mayne AM, Yoshinaga-Itano C, Sedey AL, Carey A. Expressive vocabulary development of infants and toddlers who are deaf or hard of hearing. Volta Review. 2000;100:1-28.
93 Calderon R, Naidu S. Further support of the benefits of early identification and intervention with children with hearing loss. Volta Review. 2000;100:53-84.
94 Watkin P, Baldwin M, Dixon, R, Beckman A. Maternal anxiety and attitudes to universal neonatal hearing screening. Br J Audiol. 1998:27-37. [pmid: 9643305].
95 Barringer DG, Mauk GW. Survey of parents perceptions regarding hospital-based newborn hearing screening. Audiol Today. 1997;9:18-19.
96 Kennedy CR Controlled trial of universal neonatal screening for early identification of permanent childhood hearing impairment: coverage, positive predictive value, effect on mothers and incremental yield. Wessex Universal Neonatal Screening Trial Group Acta Paediatr Suppl 1999 88(432):432 73
97 Watkin PM Neonatal otoacoustic emission screening and the identification of deafness Arch Dis Child Fetal Neonatal Ed 1996 74(1):F16 25 8653430
98 Norton SJ, Gorga MP, Widen JE, Folsom RC, Sininger Y, Cone-Wesson B, et al Identification of neonatal hearing impairment: evaluation of transient evoked otoacoustic emission, distortion product otoacoustic emission, and auditory brain stem response test performance Ear Hear 2000 21(5):5 508 10708068
99 Dalzell L, Orlando M, MacDonald M, A. B, Bradley M, Cacace A, et al The New York State universal newborn hearing screening demonstration project: ages of hearing loss identification, hearing aid fitting, and enrollment in early intervention Ear Hear 2000 21(2):2 118
100 Spivak L, Dalzell L, Berg A, Bradley M, Cacace A The New York State universal newborn hearing screening demonstration project: inpatient outcome measures Ear Hear 2000 21(2):92 103 10777017
101 Johnson JL, Kuntz NL, Sia CC, White KR, Johnson RL Newborn hearing screening in Hawaii Hawaii Med J 1997 56(12):12 352
102 Mason S, Davis A, Wood S, Farnsworth A Field sensitivity of targeted neonatal hearing screening using the Nottingham ABR Screener Ear Hear 1998 19(2):2 91
103 Thomson V The Colorado Newborn Hearing Screening Project Am J Audiol 1997 6(3):3 74
104 Thomson V, Rose LB, O'Neal J, Finitzo T Statewide implementation of universal newborn hearing screening Semin Hear 1998 19(3):3 287
105 Priesler G The development of communication and language in deaf and severely hard of hearing children: implications for the future Int J Pediatr Otorhinolaryngol 1999 49Suppl 1:S39 43 10577773