# Evidence Tables

Evidence Table 1. Studies reporting speech and language outcomes

Study, Year, Location | Study Design | Population | Exposure & Treatment | Confounders | Outcomes | Age at Testing | Results | Comments
Yoshinaga-Itano, 2000^ 87 ^ Colorado | Retrospective study of children enrolled in the Colorado Home Intervention Program (CHIP) | 25 matched pairs of children enrolled in CHIP program since 1996 | UNHS program. Children born in a hospital with a UNHS program in effect at time of birth were compared to children born in in a hospital without a UNHS program in effect at time of birth | Children matched on degree of hearing loss (mild moderate, moderately-severe, profound), cognitive quotient and age at time of speech & language evaluations. No confounding by gender, ethnicity, presence of multiple disabilities, mode of communication, education of primary caregiver, chronological age. All children enrolled in CHIP program for treatment and therapy. This is a program that emphasizes parental involvement | Receptive, expressive and total language skills. Minnesota Child development Inventory (MCDI) used to measure expressive language and comprehension-conceptual (receptive language). Parent report measure used. MacArthur Communicative Development Inventory used to measure vocabulary words produced by child with either spoken or sign language. Videotape of parent/child interaction (25 minutes). Language quotient (LQ) calculated by dividing the child's age score by chronological age and multiplying by 100. Total LQ is an average of receptive and expressive LQ scores. Scores 80 and above are considered normal language scores, 70-80 is borderline normal and 70 and below indicates language delay. Discrepancy quotient scores (DQs) calculated to measure children's language relative to cognitive ability. DQ=CQ-total LQ. A high DQ score indicates a large lag in language compared to a population without hearing loss. | 9-59 months; pairs matched on age of testing | Mean scores for expressive, receptive and total language within normal range for screened group and 18-21 points higher (p<.001) than unscreened group whose scores indicated language delay. Mean scores, screened compared to unscreened were: expressive language 82.9 (SE 3.7) vs 62.1 (SE 4.3), receptive language-81.5 (SE 3.7) vs 66.8 (SE 4.0); total language-82.2 (SE 3.3) vs 64.4 (SE 3.9). Discrepancy quotient scores (DQs) were significantly lower in screened group (14.8 vs 34.5), p<.001. DQ evaluated by both screening and age-of-identification categories. Children identified prior to 6 months (whether in screened or unscreened group) had significantly lower DQ scores indicating a smaller gap between language development and cognitive ability. Language development (total LQ) was within normal range for 56% of screened group compared to 24% of unscreened group. Delayed language development (<70) was present in 24% of the screened group compared to 68% of unscreened group. | Study results indicate children exposed to UNHS have significantly better speech and language development than children who do not have the opportunity of screening at birth. Expressive vocabulary for the 75th percentile of the screened group was ten times greater (500 vs 50 words) than the 75th percentile of the non-screened detected group. Differences in language outcomes appear to be due to early identification of hearing loss. Results in agreement with the larger cohort study of Yoshinaga-Itano, 1998. Children matched on most important contributors to language development. no confounding by other factors. Cases and controlls enrolled in CHIP program which is parent centered and uniform throughout state.
Yoshinaga-Itano, 1998^ 88 ^ Colorado | Retrospective cohort study Convenience sample from population- based program (CHIP) | n=150; ages 13 mos-3 yrs 72 < 6 mos 78>6 mos; severe & profound loss 34% early identified gp & 46% late identified group | Identification & treatment of HL prior to 6 mos of age; Colorado Home Intervention Program (CHIP) | Gender, ethnicity, mother's education Medicaid status, degree of HL, mode of communication, multiple handicaps age at data collection, cognitive ability CQ <80 vs > 80 CQ=Play Assessment Qx age score/ chronological age x 100. Cognitive status measured using tests that are not influenced by hearing or language. | Receptive and expressive language skills. Minnesota Child Development Inventory (MCDI). Calculate language quotient (LQ) for receptive expressive & total language. LQ=100 if chronlogical age same as language level | Age at data collection 13-36 months. Time between identification of HL and hearing aid fitting 2 months for early group (gp 1) and 1 month for late group (gp 2) | Receptive LQ, expressive LQ, total LQ higher in early identified group compared to group identified > 6mos (ANCOVA p>0.001). Adjusted mean LQs 79.6 (sd=25.8) receptive language, 78.3 (sd=26.8) expressive language, 79.0 (sd=25.6) early group compared to later identified group LQs adjusted mean LQs 64.6(sd=20.9) receptive language, 63.1 (sd=19.8) expressive language, 63.8 (sd=19.3). No difference in LQs between 4 age of identification levels in late group. Number of subgroup analyses performed to evaluate the effect of demographic variables. | Best study found which evaluates the effect of early identification and treatment on language skills. Appropriate statistical measures used to adjust for confounding variables, particularly CQ. Source of cases not described- What proportion of HOH children in age range 13 mos-3 years does this represent? Screening and detection program not described. Colorado has had HRR screening for a number of years and more recently added UNHS. No information on premature delivery in either group. Severity of hearing loss greater in late identified group. No trend test.
Yoshinaga-Itano, 1998^ 27 ^ Colorado | Retrospective Cohort study Convenience sample from population based program (CHIP) | n=82; age of identification 34 < 6 mos 48 > 7-18 mos; early gp 42% severe/ profound loss vs 67% severe/ profound loss late gp | Identification & treatment of HL prior to 6 mos of age; CHIP | Gender, degree of HL, cognitive function, age at identification, other disabilities (30%), DQ< 60 excluded SES-those from HRR predominately medicaid | Receptive and expressive language skills. Minnesota Child Development Inventory (MCDI); MacArthur Communication Development Inventory (CDI) | Age at data collection; early gp 19-36 months mean age 26.5 (sd=5.9) late gp 27.6 (sd=5.1) | Early gp had higher levels of receptive & expresive language, personal social development, expressive and receptive vocabulary, general development, situational comprehension and vowel production. ANCOVA for age of identification and degree of hearing loss controlled for CQ conducted on dependent measures. Adjusted means for early gp: expressive language 76.2, comprehension-conceptual 82.1, receptive vocab 200, expressive vocal 117 vs 56.6, 58.3, 86.4 and 54.6 for late gp | Early group identified from HRR, source of late gp not specified; presume referred to CHIP by usual care. All children in study selected from CHIP database if there was information on age of identification, degree of hearing loss, cognitive functioning, and chronological age at time of testing. Early group had higher % of children with mild-moderate loss and additional disabilities than did late group; < 6 mo group found mainly via HRR; late gp referred by usual care. Study sample included all children in CHIP database with required information
Yoshinaga-Itano, 1998^ 89 ^ Colorado | Retrospective Cohort study Convenience sample from population based program (CHIP) | n=40; age of identification 15 < 6 mos 25 >18 mos ; Early gp 47% severe/ profound hl, late gp 52% severe/ profound HL | Identification & treatment of HL prior to 6 mos of age. Colorado Home Intervention Program (CHIP) | Gender, degree of HL, cognitive function, age at identification, other disabilities (30%), DQ< 60 excluded SES-those from HRR predominately medicaid | Receptive and expressive language skills. Minnesota Child Development Inventory (MCDI); MacArthur Communication Development Inventory | Early gp-mean age 39.9 months sd-11.9; late gp- 40.7 sd-10.7 | Adjusted means for expressive language and comprehension-conceptual subtests of MCDI significantly higher for early group. P<.05; Expressive lang 81.1 vs 64.3; comprehension-conceptual 84.4 vs 70.1.Children in early group have 8 month delay expressive lang and 6 mos delay receptive language compared to delay of 14 mos and 12 mos for late group. | Convenience sample of children from CHIP. Presume late identified children referred from usual care to CHIP. Children in both early and late gps similar for age at testing, hearing loss by audiologic category and self help developemental quotient. Differered only on age of identification mean age 1.9 mos vs 26 mos. ANCOVA used; small sample size. Required data on age of ID, age at testing, MCDI scores, degree of HL
Apuzzo 1995^ 90 ^ Colorado | Retrospective Cohort study Convenience sample from population based program (CHIP) | n=69; age of identification birth-2 mos n=14, 3-12 mos n=11, 13-24 n=30, 25+ mos n=12. 50% early gp severe/ profound loss vs 65% of later identified group | Identification and treatment at 4 different ages; CHIP | Exclude children with DQ <60 to control for cognitive delay; age of testing same for all 4 groups; controlled for hearing loss | Receptive and expressive language skills. Minnesota CDI MacArthur CDI | Age at testing similar for all groups, about 40 months | Early identified group(0-2 mos) scored higher on general development and expressive language subtests of MCDI than did children identified later, p<0.01 One way ANOVA used | Group identified earliest were all from HRR screening; others referred to CHIP from usual care. Small sample size. Only 2 children w profound loss in early gp. No adjustment for SES
Moeller, 2000^ 91 ^ Nebraska | Retrospective cohort study | n=112 graduates of Diagnostic Early Intervention Program (DEIP) | Received intervention through age 5. Identified by DEIP; 61 in auditoryoral program; 51 in total communication program; hearing aids, FM trainers and appropriate speech/lang-uage therapy | Exclude children with non-verbal IQ <70 and those who did not participate in program through age 5; controlled for family involvement, degree of hearing loss and non-verbal IQ | Peabody Picture Vocab Test (PPVT), preschool language assessment instrument. Developed a 1-5 scale to rate degree of family involvement in child's educational program | age 5 ; tested at end of preschool period, at entry to kindergarten | Multiple linear regression used. Age of enrollment and degree of family involvement significantly correlated with higher vocabulary scores controlling for IQ and degree of hearing loss. Family involvement accounted for 57% of variance in vocab scores and age of enrollment an additional 11.5% Children enrolled prior to 11 months had stronger vocab and reasoning skills than later-enrolled children; early enrolled children within range of hearing peers. Vocab scores decreased as age of enrollment increased (< 11mos, 11.1-23 mos, 23.1-35 mos, >35mos) | Children received periodic hearing and language evaluations during preschool intervention program. 110/112 (98%) in structured program 67/112 (59.8%) had severe (n=20) or profound (n=47) hearing loss.
Mayne, 2000^ 92 ^ Colorado | Cohort study | 113 children enrolled in CHIP program. Ages 24-37 months | CHIP intervention described in previous studies | No factors found to be associated with language development in deaf. Had information on degree of hearing loss, mode of communication, age of identification, presence of other handicaps, parents hearing status, IQ as measured by cognitive quotient (CQ), mother's education, ethnicity, SES, CQ>-80 vs CQ<80. | Expressive vocabulary as measured by MacArthur Communicative Development Inventory | Continuing evaluation as part of the CHIP program | Bivariate regression models. Full model explained 56% of variance in expressive vocabulary scores. Expressive vocabulary higher with increased age, increased CQs, identification of hearing loss by the age of 6 months and having a hearing loss as the only medical condition. Normative data presented for deaf and hard-of-hearing children, ages 8-37 months. | Study identified factors contributing to variations in expressive vocabulary scores in a group of deaf and hard-of-hearing children 24-37 months. Effects of gender and SES not determined. However, these variables had no effect in this study. Excellent literature review of language development in children with normal hearing and review of language development and school performance in the deaf and hard-of-hearing.
Calderon, 2000^ 93 ^ Washington | Retrospective cohort study | 80 children enrolled in Early Child Hearing Intervention (ECHI) program, a home based total communication program in western Washington. Cohort grouped by 3 levels by age of entry into program: <1 year (n=9), 12-24 months (n=39), >24 months (n=32) | Early identification and treatment. All children had profound hearing loss and all had been fitted with hearing aid or cochlear inmplants. | Controlled for degree of hearing loss, degree of outcome impairment that was present upon entry into program (baseline test levels). Excluded children with developmental delay. | Receptive and expressive language development, pre- and post-test auditory development and speech production skills. Evaluated at 3 years, at end of program. | Entry to program and at 36 months. Pre and post measures used | ANOVA and multiple regression used. Age at entry to program explained 40% of the variance within the data. Significant trend for age at intervention, suggesting that children with an intervention at < 1 year had better outcomes than children with interventions at 12-24 months, who in turn had better outcomes than children starting even later, at 24 months. No benefit found for age at identification and speech and auditory scores. | All children enrolled in same program with continuous records and testing. Pre/post measures same for all in group. Review of literature on normal language development landmarks.

Evidence Table 2. Quality rating of cohort studies reporting language outcomes

Study, Year (Quality) | Selection of Subjects | Comparability and Maintenance of Early vs Late Groups | Adjustment for Confounders | Results
Studies from Colorado Home Intervention Program (CHIP)
Apuzzo, 1995^ 90 ^(FAIR) | Convenience sample of 69 high-risk infants diagnosed between 2 and 25 months of age. Children with severe cognitive delay were excluded. | Late-identified group was more likely to have severe to profound hearing loss (65% vs 50%). No report of attrition or followup rates. | One-way ANOVA did not adjust for SES, family involvement, or other potential confounders. | At 40 months of age, infants identified before 2 months of age had higher mean Minnesota Child Development Inventory (MCDI) scores for expressive language (p<0.01).
Yoshinaga-Itano, 1998^ 89 ^(POOR) | Convenience sample of 40 high-risk infants, divided into those identified and treated before 6 months of age (n=15) and those treated after 18 months (n=25). Children with severe cognitive delay were excluded (DQ<60). | Late-identified group was more likely to have severe to profound hearing loss (52% vs 47%). No report of attrition or followup rates. | Gender, severity of hearing loss, cognitive function, and other disabilities were examined in 2-way ANCOVAs, not in a multiple regression (no simultaneous adjustment for multiple confounders). | At 40 months, infants identified before 6 months of age had better adjusted mean MCDI scores for expressive language (81.1 vs 64.3, p<0.05 ) and receptive language (84.4 vs 70.1, p<0.05).
Yoshinaga-Itano, 1998^ 27 ^(POOR) | Convenience sample of 82 infants, 19 to 36 months of age, with mild to profound PHL, divided into those identified before 6 months of age (n=34) and between 7 and 18 months of age (n=48). Early group identified by high-risk registry; late group by usual care. Children with severe cognitive delay were excluded (DQ<60). | Late-identified group was more likely to have severe to profound hearing loss (77% vs 42%). No report of attrition or followup rates. | Gender, severity of hearing loss, cognitive function, and other disabilities were examined in 2-way ANCOVAs, not in a multiple regression (no simultaneous adjustment for multiple confounders). | At 26 months, infants identified before 6 months of age had better adjusted mean MCDI scores for expressive language (76.2 vs 56.6, p=0.001), receptive language (82.1 vs 58.3, p=0.002), MacArthur CDI adjusted mean receptive vocabulary (200 vs 86.4, p<0.001), and expressive vocabulary (117 vs 54, p<0.03).
Yoshinaga-Itano, 1998^ 88 ^(POOR) | Convenience sample of 150 children 13 to 36 months of age with mild to profound PHL, divided into those identified before (n=72) or after (n=78) 6 months of age. The number of low-risk infants and the role of UNHS in identifying subjects are not described. Selection bias is likely because the design probably excluded infants who were diagnosed to have hearing loss but did not enter the program, or who entered, but were lost to followup. | At baseline, compared groups differed in some demographic characteristics and in the proportion of subjects with cognitive impairment and severe to profound hearing loss (CQ <80, 29% early group vs 56% late group; severe to profound hearing loss 34% early group vs 46% late group). No report of attrition or followup rates. | There was stratification by CQ (<80 vs >80). Other covariates (gender, minority status, maternal education level, Medicaid status, severity, mode of communication, other disabilities) were examined singly in 2-way ANCOVAs. | At 13 to 36 months, adjusted mean MCDI receptive language LQ was higher for those identified before 6 months (79.6 vs 64.6, p<0.001). Mean MCDI expressive LQ was higher (78.3 vs 63.1, p<0.001) and total language (79 vs 64, p<0.001) was higher in early-identified group. No differences in LQ among 4 age of identification levels in late-identified group.
Mayne, 2000^ 92 ^(POOR) | Convenience sample of 113 children 24 to 73 months of age, divided into those diagnosed before and after 6 months of age. The number of low-risk infants and the role of UNHS in identifying subjects are not described. Overlap of sample with previous CHIP studies was not reported. | Demographic comparisons of the groups were not reported. No report of attrition of followup rates. | Regression analysis adjusted for degree of hearing loss, mode of communication, other disabilities, parents' hearing, cognitive quotient, mother's education, ethnicity, SES | At 24 to 36 months, age at diagnosis explained 23% of the variance in expressive language scores.
Studies from other programs
Moeller, 2000^ 91 ^(FAIR) | Convenience sample of 112 5-year-olds who completed the Diagnostic Early Intervention Program in Lincoln, Nebraska. Children with non-verbal IQ <70 and those who did not participate in program through age 5 were excluded. The number of low-risk infants and the role of UNHS in identifying subjects are not described. Outcome assessments were made pre- and post-intervention. | Not reported. No report of attrition or followup rates. Early identified children may have more opportunity to drop out, although differential drop out may be less of a problem at 5 years than in studies assessing closer to enrollment. | Multiple regression analysis adjusted for family involvement, degree of hearing loss and non-verbal IQ. | At age 5, family involvement accounted for 57% of variance in vocabulary and age of enrollment accounted for 11.5%. Adjusted mean vocabulary and reasoning scores were within normal range among children enrolled prior to 11 months but were lower for later-identified children.
Calderon, 2000^ 93 ^(FAIR) | Cohort of 80 children with profound hearing loss enrolled in Early Child Hearing Intervention (ECHI) in Seattle Washington. Children with developmental delay were excluded. Cohort grouped by 3 levels by age of entry into program: <1 year (n=9), 12-24 months (n=39), >24 months (n=32). The method of sampling is not described, but the design excluded patients who entered the program but did not graduate. | Not reported. Late diagnosed group had less severe-to-profound loss (36% vs 66%). Overall loss to followup not reported. Because the early-diagnosed group were in the program longer, they had more opportunity to drop out, so a differential loss to followup is likely. | Controlled for degree of hearing loss, degree of outcome impairment that was present upon entry into program (baseline test levels). | At 3 years, age at entry to program explained 43.5% of the variance in receptive language and 49% of the variance in expressive language. Children treated before 2 years had better outcomes than those treated after 2 years. Only 3 children entered the program prior to 6 months of age.

ANOVA indicates analysis of variance; SES, socioeconomic status; DQ, developmental quotient; ANCOVA, analysis of covariance; PHL, permanent hearing loss; UNHS, universal newborn hearing screening; CQ, cognitive quotient; LQ, language quotient; SE, standard error