# Discussion

## A. Summary of Benefits and Harms

Table 4 summarizes the benefits and harms of UNHS and selective screening in a hypothetical cohort of 10,000 newborns. We used the results of our literature review to estimate prevalence, sensitivity and specificity, compliance, and the likelihood of being diagnosed and treated before 10 months of age. To estimate PPV, the results of the Wessex trial are used. Although other screening studies found better PPVs, we used this estimate (6.7%) because it comes from the only controlled trial, and is the best evidence about screening.

Table 4. Benefits of screening a hypothetical cohort of 10,000 newborns for moderate to profound PHL

Benefit and Relevant Factors | Probability or effect size | UNHS | High-risk screening
Assumptions*
Proportion high risk | 0.2
Prevalence
High risk group | 0.008
Low risk group | 0.0008
Miss rate for UNHS (proportion not screened in hospital)
in high risk | 0.1
in low risk | 0.05
followup rate for misses | 0.9
Miss rate for high-risk screening
in high risk^ | 0.2
followup rate for misses | 0.75
Sensitivity of 2-stage screening | 0.85
Specificity of 2-stage screening | 0.97
Compliance with followup | 0.9
Accuracy of diagnostic ABR
Sensitivity^ | 1
Specificity | 0.995
Proportionof low-risk diagnosed before 10 months without screening^ | 0.35
Treated before 1 year | 0.6
Results
Number of infants screened | | 9400 | 1600
Cases diagnosed before 10 months | | 17 | 12
Cases treated before 10 months | | 10 | 7
out of total | | 22 | 22
“False Positive” screening tests | | 254 | 48
Normal infants incorrectly diagnosed to have PHL at first post-hospital audiologic examination | | 1 | 0
NNS to diagnose 1 case | | 584 | 173
NNS to diagnose 1 additional case before 10 months | | 1441
NNS to treat one additional case before 10 months | | 2401

PHL indicates permanent hearing loss; NNS, number needed to screen; ABR, automated brainstem response

UNHS=universal newborn hearing screening

* Base case assumptions are derived from the studies in Table 2, except for those marked with ^.

There are no reliable data by which to estimate how often selective screening misses patients whose risk factors were not detected during hospitalization. We assumed that in a selective screening program, 20% of high-risk infants are never tested in the hospital, versus 10% for UNHS. There are also no reliable data by which to estimate the probability that a low-risk infant will be diagnosed by 10 months without newborn screening; we estimated this to be 35% in our base case.

With UNHS, an additional 7800 screening tests would be done, resulting in the diagnosis of 6 additional cases of moderate to profound hearing loss diagnosed before 10 months of age. Of these, 3 additional cases would be treated before 10 months of age. Thus, the number needed to screen (NNS) to detect 1 additional case before 10 months would be 1441, and the NNS to treat 1 additional case before 10 months would be 2401. With UNHS, 254 newborns would be referred for audiological evaluation because of false-positive second-stage screening test results, versus 48 for selective screening. Of these, 1 would be falsely diagnosed to have permanent hearing loss at the first post-hospital visit to an audiologist.

Of the 6 additional early-diagnosed, low-risk newborns, how many would actually benefit from early treatment? The data needed to estimate this -- the probabilities of a poor language outcome with and without early treatment -- are not known. To use a hypothetical example, if 50% of low-risk newborns would have poor language ability if diagnosed after 10 months, and early intervention reduced this by 50%, then the number needed to screen to prevent 1 additional case of delayed language acquisition would be 6771.

## B. Conclusions

Table 5 summarizes the evidence for each of the major assumptions underlying the case for UNHS. The quality of the evidence ranged from good to poor; evidence codes are explained in Table 5.

1. There is evidence from population-based surveys that diagnosis and treatment are delayed until after age 1 or 2 in many children who have congenital hearing impairment. This is particularly true for children who were at low risk for hearing impairment at birth (Level II-2 Evidence).
2. There is anecdotal evidence that these delays result in anxiety and stress on the family or the child (Level III Evidence).
3. Hearing impairment is associated with poor reading and language performance in school and under-employment or unemployment. Delay in diagnosis and treatment is one of many factors associated with these consequences. Later diagnosis is associated with delayed development in vocabulary, grammar, and conversation in preschool children (Level II-3 Evidence). However, the burden of illness has not been directly measured in the main subgroup of children targeted by universal screening -- those who have no risk factors for hearing impairment at birth.
4. Technically, OAE and ABR are highly accurate screening tests for congenital hearing impairment (Level II-1 Evidence). In newborns who have risk factors for hearing loss, to achieve a specificity of 90%, the sensitivity of the ABR was 84%. Their accuracy in low-risk newborns has not been carefully studied.
5. The positive predictive value of the two-stage screening protocol (OAE followed by ABR) for the diagnosis of moderate-profound bilateral permanent hearing loss is close to 7% (Level II-2 Evidence). In practice, the protocols used to define a positive test, and consequently the rates of false positive test results, vary widely (up to 10-fold).
6. In expert hands, audiological assessment before 3 months of age results in about one false diagnosis of permanent hearing impairment for every 15 correct diagnoses (Level II-1 Evidence). Studies of screening have not adequately described how often audiological assessment must be repeated, and how often results are indeterminate or false alarms.
7. UNHS increases identification of deaf and hearing-impaired infants compared with selective screening, but several information gaps make it difficult to estimate the difference with confidence. One controlled study in the United Kingdom suggests that, for infants with moderate and severe hearing losses, screening led to the diagnosis and treatment before 10 months of age of one additional case for every 7216 low-risk newborns screened. (Level II-1 Evidence) Several time series demonstrate that the average age of identification decreased as use of UNHS increased,(Level II-3 Evidence), but these trends also reflect improved coordination of care as well as improved screening coverage.
8. No prospective cohort studies or controlled trials have followed screened and non-screened groups over time to evaluate language outcomes. One cohort study found receptive, expressive, and total language scores of children born in a hospital with UNHS program were 18-21 points higher (p<.001) than children born in hospitals without UNHS (Level II-2 Evidence -- poor). Several other cohort studies show that, by 2 to 4 years of age, children who have had hearing aids and other therapy in the first 6 months of life had better language skills than those who have had hearing aids and other therapy for shorter periods of time (Level II-2 Evidence -- fair to poor). While they are better than older studies, these studies had serious flaws and did not specifically describe the subgroup of children who would be identified by universal screening but not by selective screening.
9. Information on the short and long-term adverse effects of screening and early treatment is inadequate (Level III Evidence). No studies have examined whether early intervention adversely affects the child or the parent-child relationship.

Table 5.Strength of evidence for universal newborn hearing screening

Key Question | Evidence Code | Quality of Evidence
1. Can UNHS accurately diagnose moderate to severe sensorineural hearing impairment?
Does UNHS improve the yield of screening, compared with selective screening of high-risk newborns? In UNHS increases identification of deaf and hearing-impaired infants between 18.5% and 33% over selective screening in high-risk children. | II-1, II-3 | Good: Consistent results from several cohort studies that recorded risk factors to estimate the proportion of cases that had no risk factors. However, no controlled trials of UNHS versus selective screening have been done.
What are the sensitivity, specificity, and predictive value of screening tests? OAE and ABR are highly accurate screening tests for congenital SNHL and are clearly more accurate than home visitor screening (using the response to noise as a screening test at ages 6 to 12 months). | II-1 | Good: One controlled trial measured the predictive value of a positive test result, 6.7%, and a good quality cohort study measured sensitivity and specificity against an independent gold standard.
In screening programs, how many children are identified and treated before six months? UNHS increases the chance that diagnosis and treatment will occur before 6 months of age. | II-1, II-3 | Fair: One controlled study in the United Kingdom and one cohort study in the U.S. reported the frequency of treatment before 10 and 5 months, respectively. Other studies did not provide sufficient information, and none included patients who, although screened, were diagnosed and treated late because of loss to followup.
2. Does screening improve language and communication skills? Evidence is inconclusive. | II-2 | Poor: One matched, retrospective study with selection bias and other flaws. No well-conducted controlled studies that compare language outcomes in children identified by UNHS to those identified by usual care or selective screening.
3. Does identification and treatment prior to 6 months improve language and communication in infants who would not be diagnosed that early in a selective, high-risk screening program? Evidence is inconclusive. | II-2, II-3 | Fair/Poor: Studies suffer from selection bias and baseline differences between compared groups. These studies did not specifically describe outcomes in the subgroup of children who would be identified by UNHS but not by selective screening.
4. What are the potential adverse effects of screening and of early treatment? | III | Poor: Most postulated adverse effects have not been evaluated in studies.

Evidence codes: I, Randomized, controlled trial; II-1, Controlled trial without randomization; II-2, Cohort or case-control analytic study; II-3, Multiple time series, dramatic uncontrolled experiments; III, Opinions of respected authorities

## C. Future Research Needs

Gaps in the evidence about the effectiveness of screening are striking. These gaps are best highlighted by comparing UNHS to other screening programs that are considered to be strongly supported by evidence. For some screening proposals, such as mammography or chlamydia testing, randomized trials of screening have proven effects on health outcomes, such as breast cancer mortality or pelvic infections. For other screening programs, such as those for hyperlipidemia, diabetes, and depression, the efficacy of the proposed treatments has been proven, and the key issue is whether patients who would be identified by screening are sufficiently similar to those included in the randomized trials of treatment. For UNHS, there are no good-quality controlled studies of the clinical benefit of screening, and the research basis for intense early intervention is poor. There are no trials in which early-identified infants are assigned to intense early intervention programs versus expectant management or more conservative approaches.

Gaps in information about UNHS and about alternatives to UNHS remain. While selective screening of high-risk newborns can be justified on the grounds of high prevalence, evidence about the effectiveness of early treatment is no stronger for selective screening than it is for UNHS. Moreover, the ability to identify risk factors in a timely and accurate way is an essential component of the selective screening strategy, but is also poorly studied. Other alternatives to universal screening of newborns include high-risk screening or referral for screening on broad indications at 6 to 12 months of age, when screening tests and audiometric examination are more reliable. These alternatives have not been examined in the literature.

If randomized trials are not done, good-quality longitudinal studies of UNHS versus a high-risk approach or no formal screening are needed to address:

- The gains in case finding by UNHS.
- Quantification of the consequences of false-positive screens and false-negative screens to determine if there are clinically important harms that result from screening.
- Speech, language, and scholastic achievement of deaf and hard-of-hearing children followed over time. These would be examined by method of detection -- for example, UNHS, HR, clinical practice and timing (early vs. late) and include information on other important factors that contribute to speech, language and scholastic achievement.
- Comprehensive cost-benefit analyses that include cost of tracking and followup of all children screened. Issues of cost and cost-benefit can be studied from a narrower health care delivery organization's point of view and/or a broader societal perspective. In integrated delivery systems such as HMOs, issues of total and marginal direct medical costs and patterns of care could be addressed.
- Registries that are part of integrated service delivery systems should be encouraged at the city, county, or state levels. These registries could play a vital role in routinely collecting information on known and potential confounders as well as speech and language outcome data. In order to answer the service delivery and developmental questions an integrated screening, an evaluation and followup system with universal access is needed. The requirements are similar to those for congenital metabolic defects such as phenylketonuria (PKU) or hypothyroidism.
- Large-scale screening, intervention, and longitudinal followup studies with developmental outcome measurement for UNHS. Early Hearing Detection and Intervention Health Resources and Services Administration programs might provide funding and vehicles for this research.