# Results

## A. Accuracy of Screening Tests

### 1. Can UNHS Accurately Diagnose Moderate to Severe Sensorineural Hearing Loss?

Since 1995, 10 publications provided new information about the yield of screening and the performance of OAE and ABR in actual screening programs (Table 2). These include a controlled trial conducted in Wessex, United Kingdom;^ 79 ^ 5 screening programs at selected hospitals in Rhode Island,^ 14 ^ Hawaii,^ 71 ^ Colorado,^ 81 ^ Texas,^ 80 ^ and New York;^ 40 ^ and 4 hospital-based programs, in New Jersey,^ 82 ^ Whipps Cross, United Kingdom,^ 97 ^ France,^ 84 ^ and North Carolina.^ 85 ^

Table 2. Studies of universal newborn hearing screeing

Author Year | Description (Quality Rating) | Screening Tests | # Screened/ # Available (% Screened) | Yield & NNS to find 1 case of bilateral PHL | # Positive Screen (%) # Follow-up %Lost to Follow-up | Definition of High-Risk | # Low-Risk Identified/ # Screened NNS | #High Risk Identified/ #Screened NNS | True positive/Total positive tests PPV | PPV (LR) Calculated by Overall NP rate | PPV (HR) Calculated by Overall NP rate
Wessex 1998^ 79 ^ | Controlled, nonrandomized trial from 4 hospitals of 25,609 from 10/93 to 10/96 (Good) | TEOAE followed by ABR | 21,279/25,609 (83%) | 23/21,279 925 | 342 (1.6%) NR NR | NIH Criteria | 7/19,555 2,794 | 20/1,724 86 | 23/342 6.7% | 2.2%* | 72.5%*
Prieve 2000^ 40 ^ | State-wide demonstration project from 7 perinatal centers, 8 hospitals in New York (Good) | TEOAE followed by TEOAE or ABR in birth admission; TEOAE, ABR at 4-6 weeks (stage 2) | 69,766/71,922 (97%) | 49/69,736 1422 | 4699 (6.5%) 1st stage See footnote* 43.4% | NICU infants | 33/NR 2041† | 52/NR 208† | NR 4.5% (stage 1) 22.1% (stage 2) | 2.2% | 12.5%
Vohr 1998^ 14 ^ | Cohort from 8 maternity hospitals in Rhode Island from 1/93 to 12/96 (Fair) | TEOAE followed by: ABR (HR infants) TEOAE and ABR in 2-6 weeks (LR infants) | 52,659/53,121 (99%) | 79/52,659 666† | 5,397 (10.2%) 1st stage 677 (1.3%) 2nd stage 4,575 15.2% | NICU infants | 61/47,529 779‡ | 50/5,130 103‡ | 79/5,397 1.5% (stage 1) 79/677 11.7% (stage 2) | 9.9%* | 75%*
Finitzo 1998^ 80 ^ | Cohort from 9 Texas hospitals from 1/94 to 6/97 (Fair) | ABR or TEOAE in birth admission followed by either ABR or TEOAE at 1-8 weeks | 52,508/54,228 (97%) | 20/17,105 855† § | 1,787 (3.4%) 1,224 31.5% | NR | NR | NR | 113/1,787 6.3% or 113/1,224 9.2% (stage 1) Total positive NR (stage 2) | NR | NR
Barsky-Firsker 1997^ 82 ^ | Hospital-based series at Saint Barnabas Medical Center, New Jersey 1/93 to 12/95 (Fair) | ABR by audiologists. (One-stage) | 15,749/16,229 (97%) | NR | 485 (3.1%) NR NR | NICU infants | 29/14,014 483 | 23/1,735 75 | 52/485 10.7% | 6.7%* | 42.8%*
Watkin 1996^ 83 ^ | Hospital-based series at Whipps Cross Hospital, England (Fair) | TEOAE followed by TEOAE and ABR within 4 weeks | 11,606/14,353 (81%) | 19/11,606 755 | 337 (2.9%) 290 14% | Risk Factors and/or NICU infants | 7/NR | 13/NR | 18/337 5.3% or 18/290 6.2% (stage 1)
Mehl 1998^ 81 ^ | Cohort from 26 hospitals in Colorado from 1992 to 1996 (Poor) | 19 ABR, 1 TEOAE, 6 ABR Follow-up screen not reported | 41,796 /NR | NR | 2709 (6.5%) 1,296 52.2% | NR | NR | NR | 75/2,709 2.8% or 75/1,296 5.8% (stage 1) | NR | NR
Aidan, 1999^ 84 ^ | Hospital-based series in Paris, France of infants in normal newborn nursery (Poor) | TEOAE in 48 hours; TEOAE within 4 weeks | 1,421/1,727 (82%) | 2/1,421 711 | 238 (16.7%) 123 48.3% | hypoxemia, hyperbili-rubinemia, FH | 2/1,421 711 | NR | 2/238 0.8% or 2/123 1.6% (stage 1) 2/9 22.2% (stage 2) | 2/238 (stage 1) 0.8% 2/9 (stage 2) 22.2% | NR
Clemens 2000^ 85 ^ | Hospital-based series in North Carolina (Women's Hospital of Greensboro) from 7/98 to 6/99 (Poor) | ABR followed by re-test for fails (stage 1a) or ABR (stage 1b); outpatient ABR and diagnostic ABR (stage 2) | 5010/5034 (99.5%) | NR | 103/5,054 85 17.5% | NICU infants | NR | 4/454 114 | 9/103 (stage1a,b) 8.7% 9/15 (stage 2) 60% unilateral and bilateral losses | 9/103 8.7% | 4/5 80% (one patient lost to follow-up)
Mason 1998^ 102 ^ | Series of infants born at Kaiser, Honolulu from 3/92 to 2/97 (Poor) | ABR | 10,372/10,773 (96%) | 12/10,372 864 | 415 (4.0%) 362 12.8% | NICU infants | 5/8,971 1,794 | 7/1,401 200 | 15/415 3.6% or 15/362 4.1% (stage 1) total positive NR (stage 2) | 2.2%* | 12.5%*

ABR indicates automated auditory brainstem response; TEOAE, transient evoked otoacoustic emissions; NIH, National Institutes of Health Consensus Development Conference; LR, low-risk; HR, high-risk; NICU, neonatal intensive care unit; FH, family history; NR, not reported; NNS, number needed to screen; PHL, permanent hearing loss (moderate or worse)

*Reported different rates for misses and fails

†Includes mild, bilateral hearing loss

‡Includes unilateral hearing loss

§Data reported for 1996 only

### 2. What are the sensitivity and false negative rate of screening tests?

In most studies, the sensitivity of the screening test could not be assessed, because newborns who passed the initial screen did not undergo further evaluation. Three studies, a controlled trial of UNHS in Wessex,^ 79 ^ a hospital based program in England, ^ 83 ^ and a report of statewide screening in Rhode Island,^ 14 ^ provided some information about sensitivity and about the false negative rate of the screening test (1-sensitivity). These studies reported the number of cases missed by screening and eventually diagnosed by other means, but they did not make a comprehensive effort to follow babies who had normal screening test results. The false negative rates were 15%,^ 79 ^ 6%,^ 14 ^ and 11%.^ 83 ^

A non-randomized, controlled, unblinded trial of UNHS was conducted in the Wessex district of the United Kingdom.^ 79 ^ Over a period of 3 years, neonatal screening alternated with usual care every 4 to 6 months in 4 maternity hospitals. During the periods of neonatal screening, 21,279 of 25,609 eligible children (83%) had a TEOAE test followed by ABR testing for those with a positive TEOAE test. Newborns with positive ABR results were referred for audiological testing. A total of 28,172 babies were born during periods without neonatal screening. All children in both groups received the existing screening program, the health visitor distraction test (HVDT), a widely used screening test for hearing loss, at about 8 months of age. Children who did not pass the HVDT were also referred for audiological testing. Patients were followed for a period of 18 to 56 months, by which time the final diagnosis, age at diagnosis, and age at initiation of treatment were recorded for all children whose parents had consented to the study.

In the Wessex trial, the sensitivity of TEOAE was higher than that of the HVDT. The two-stage screening protocol identified 23 of 27 (85%) infants who proved to have hearing loss upon followup. In contrast, the HVDT identified less than one-third of newborns who proved to have significant bilateral hearing loss. As the authors note, the results for the HVDT may be better than would occur in everyday practice, because the examiners were aware that their performance was being compared to that of the TEOAE. The same applies to the performance of the TEOAE and ABR.^ 96 ^

In the Rhode Island study,^ 14 ^ over 4 years 52,659 infants born at 8 maternity hospitals in the state had a TEOAE and ABR done. The program identified 79 infants with bilateral hearing loss and 27 with unilateral hearing loss. Children with negative test results and no risk factors for hearing loss were assumed to be true negatives. These children did not receive the gold standard evaluation at 6 to 8 months of age. Nevertheless, 5 infants who passed birth screening were diagnosed with bilateral hearing impairment between 5 and 22 months of age (84 bilateral, 27 unilateral SNHL). The sensitivity was therefore 95% for stages 1 and 2. That is, 95% of infants who were confirmed to have hearing impairment failed their newborn hospital screening or the followup outpatient hearing screening at approximately 1 month of age.

### 3. What are the specificity, false positive rate, and predictive value of screening tests?

In the Wessex trial, the specificity of the combined screening strategy was 98.5%, meaning that 1.5% of normally hearing newborns underwent a full audiologic evaluation because of false positive screening test results.^ 79 ^ The Rhode Island group reported a specificity of 90% for TEOAE screening in the hospital, meaning that 10% of normal-hearing children underwent the second stage test.^ 14 ^

If an infant has a positive result on the screening test, how likely is it that the infant has hearing loss? Because the prevalence of congenital hearing loss is low, there are many more false positives than true positives; as a result, the positive predictive value (PPV) (number of infants with hearing loss and a positive test divided by the total number testing positive) is also low.

The programs in Table 2 used a two-stage screening protocol, in which an infant who fails the initial test (an OAE or ABR) is retested, either in the hospital or as an outpatient within 12 weeks of discharge, and is referred for audiologic evaluation if he or she fails the second test. The PPV can be calculated for either the first stage or the second stage of screening. If both stages are performed while the infant is in the hospital, the PPV of the second-stage test determines who will be recalled for followup testing as an outpatient. In one good-quality study, the overall PPV for the second-stage screening test was 6.7%.^ 79 ^ In the well-baby nursery, the PPV was 2.2%, meaning that 1 of every 45 infants referred for outpatient audiologic evaluation eventually proved to have moderate to profound bilateral SNHL. For high risk babies the PPV was 20% (18/90). None of the other studies in Table 2 provided sufficient data to determine the PPV for moderate-profound bilateral PHL. Higher estimates of the PPV reflect the inclusion of unilateral or bilateral mild hearing loss.

In the programs described in Table 2, there was no systematic difference in the performance of TEOAE or ABR when used as the initial test for screening. We identified one good-quality study that measured the sensitivity and specificity of the OAE and ABR using an appropriate behavioral gold standard, visual reinforcement audiometry.^ 98 ^ In approximately 3,000 high-risk children who underwent neonatal screening and returned for followup testing at 8 to 12 months of age, the two-stage protocol missed 11% of affected ears. The OAE was very sensitive (98%) for severe hearing loss, but was less sensitive (80%) for moderate and profound losses; at this sensitivity, the specificity of the OAE was 80%. For the ABR, sensitivity and specificity were 84% and 90%, respectively. Overall, neonatal testing resulted in a final diagnosis of bilateral moderate to profound SNHL of 1 in 230 high-risk and 1 in 2348 low-risk infants.

These estimates of test performance and yield are probably more reliable than those from actual screening programs in Table 2. In those programs, decisions about diagnosis and treatment are made on the basis of a “diagnostic ABR” performed when the infant is 1 to 6 months of age. The use of this intermediate diagnostic standard facilitates earlier diagnosis and intervention, but may overestimate the number of cases of PHL. In the Wessex trial, the first audiological examination was done when the babies were between 8 and 12 weeks of age. Of 27 diagnosed to have some degree of sensorineural hearing loss, the diagnosis was wrong in 2 (7.4%), and the babies proved to have normal hearing when re-examined at 4 months or 10 months of age.^ 96 ^ In another study,^ 83 ^ 5 (29%) of 17 infants initially diagnosed to have moderate PHL were later found to have only mild hearing loss. None of the other studies in Table 2 described follow-up procedures to determine how often the intermediate diagnosis of SNHL was incorrect.

## B. Effectiveness of Early Detection

### 1. Compared to Selective Screening of High-risk Newborns, How Many More Cases are Identified?

No studies have compared the yield of UNHS to the yield of a comparably-staffed, concurrent selective screening program. A logistical problem with selective screening is how to identify low-risk infants in a timely and accurate manner. Low birthweight and admission to a special or intensive care unit are easily identified, but it is not always possible to ascertain a family history of hearing impairment or chromosomal abnormality before hospital discharge.^ 83 ^ Uncertainty about the proficiency of selective screening makes it difficult to determine how much UNHS adds to the diagnostic yield of screening.

Overall, in the studies in Table 2, screening detected 1 case of moderate to profound SNHL for every 465 to 925 infants screened; from 779 to 2794 low-risk, and 86 to 208 high-risk, newborns were screened to find 1 case. Screening the low-risk or well-nursery population resulted in identification of 5 of the 27 (18.5%) hearing-impaired infants in the Wessex trial,^ 79 ^ 7 of 22 infants (32%) in the Whipps Cross study,^ 83 ^ 8 of 15 (53%) hearing-impaired infants in the Hawaii study,^ 71 ^ and 2 of 6 (33%) in North Carolina.^ 85 ^ All of the US studies that reported results for low-risk and high-risk groups separately defined “high-risk” as those who had NICU admission. The New York program examined differences between the NICU and well-baby nursery in detail. Overall, 1 in 884 newborns screened had bilateral hearing loss. In the NICU, where 90% of babies had other risk factors, 1 in 125 had hearing loss. In the well-baby nursery, where 30% had risk factors, 1 in 1042 had hearing loss.^40, 99^

UNHS programs vary in their ability to test all newborns and provide comprehensive follow-up and treatment services:

#### “Missed” infants

In 5 UNHS programs, from 1% to 4% of newborns were not screened.^14, 71, 78, 80, 82^ In the Wessex Trial, 17% of newborns were not successfully screened during their hospitalization.^ 79 ^ Early discharge or transfer from the hospital, lack of coverage on nights and weekends, and problems with equipment and personnel are the main factors limiting initial coverage.

Universal screening might increase early diagnosis rates in high-risk infants by reducing “miss” rates and increasing compliance with followup testing and treatment. Only one study, in New York, compared miss rates in the NICU to those in the well-baby nursery.^ 100 ^ In 8 hospitals, miss rates in the well-baby nursery ranged from 1% to 5%, but in the NICUs the miss rates ranged from 3.5% to 26%. Unfortunately, there are no comparison data to determine whether the high miss rates in the NICU are better or worse than those in the New York hospitals that used selective screening. There are also no data on the relative miss rate of selective screening and UNHS for well-baby nursery infants who have a family history or other clinically inapparent risk factors for hearing impairment.

#### Compliance with followup testing

The programs with the best compliance -- Hawaii^ 71 ^ and Rhode Island^ 14 ^ -- reported that 9% and 13% of infants with an initial positive test failed to return for further testing. Both of these programs had good computerized tracking systems.^14, 101^ Other programs reported larger numbers of infants lost to followup. The Texas UNHS program tested 68.5% (1224/1787) of children failing the initial screen;the remaining 31.5% were lost to followup.^ 80 ^ Mehl reported that 47.8% (1296/2709) of infants in Colorado completed diagnostic evaluation.^ 81 ^ In the New York program, 72% of inpatient screening failures returned for followup screening; 76.3% of NICU fails returned versus 71.9% of failures from the well-baby nursery. Only 31% of infants who missed hospital screening returned for outpatient testing. The return rate was 33.5% from the NICU population and 24.3% from the well-baby nursery.^ 99 ^

### 2. How Much Earlier are Children Diagnosed and Treated?

One indicator of the benefit of UNHS is the number of additional cases of significant hearing impairment that are diagnosed early. The rates of early diagnosis and treatment reflect the quality of communication between the screening hospital, consulting audiologists, and service providers. These mechanisms are as important as the reach and accuracy of initial testing to the success of a screening program. Studies should make clear what special mechanisms were put in place to reduce lags between referral and diagnosis, and diagnosis and treatment, that are seen in everyday care.

The Wessex trial did not directly compare the rate of early diagnosis and treatment for UNHS to that of selective screening of high-risk newborns. It did compare UNHS to no newborn screening, followed in both groups by HVDT at 8 months of age. In the Wessex trial, for infants with moderate to profound hearing impairment, UNHS increased rates of referral to an audiologist by age 6 months (an increase of 62 per 100,000; 95% CI 19-105/100,000; p=0.006), but did not increase rates of confirmation of diagnosis (p=0.22) or initiation of management within 10 months (p=0.08).^ 79 ^ Among those with moderate to severe hearing loss, however, screening led to highly significant increases in confirmation and management by 10 months of age. With UNHS, 13 out of 23 (57%) children with moderate or severe impairment were diagnosed by 10 months, whereas during the period of time without UNHS, only 2 out of 14 (14%) with hearing impairment were identified by then. ^ 79 ^ UNHS did not reduce the rate of diagnosis after 18 months, either overall (5/27 for UNHS vs 6/26 for the control group) or in the moderate to severe subgroup, but additional followup may be needed to assess effects on late diagnosis.

How much of the overall benefit in the Wessex trial can be attributed to screening low-risk infants? Of the 27 cases of moderate to profound bilateral hearing loss diagnosed during periods of universal screening, there were 5 who had no risk factors and were in the general (well-baby) nursery. In this low-risk group, 1 in 3597 screened had moderate to profound bilateral SNHL. Overall in the Wessex trial, 59% (16 of 27) babies born during periods of UNHS were diagnosed before 10 months of age. The authors do not break out how many of the low-risk cases were diagnosed before that age, but if 59% were, the number needed to screen to detect 1 low-risk infant before 10 months was 7216. ^a^

^a^ In the Wessex trial, 11 cases were from the special-care baby unit and 16 from the general ward. Of these 16, 5 had no risk factors for hearing impairment and 11 had at least one risk factor (family history, perinatal infection, anatomical deformity, birth asphyxia, chromosomal abnormality, or exchange transfusion.) Therefore, the overall yield in the general nursery -- combining infants with and without risk factors -- was one case for every 2,713 screened. Selective screening would have identified the 11 cases from the special care baby unit (SBCU) and would definitely not have identified the 5 cases from the general nursery who had no risk factors. It is impossible to determine how many of the 11 general-nursery infants with risk factors selective screening would have identified.

Except for the Wessex trial, the studies in Table 2 were uncontrolled, so the effect on the timing of diagnosis, compared with selective screening of high-risk newborns, cannot be estimated. Some reported decreases in the age at diagnosis as they became more experienced with UNHS. During the 4 years of UNHS in Rhode Island, the mean age of hearing loss detection decreased from 13.3 months at baseline to 5.7 months by year 4.^ 14 ^ In Hawaii both the average age of hearing-loss identification and fitting with hearing aids decreased as the percent of the population screened by UNHS increased. The mean age of identification was 12 months and the mean age of amplification was 16 months when 19% of the population received screening, compared to an average age of identification of 3 months, and age of amplification of 7 months with almost 95% screening coverage.^ 101 ^

Four of the 8 observational studies reported the mean age at the time of treatment. For hearing aid fitting, the mean age for all patients was 5.7 months,^ 14 ^ 5.8 months,^ 102 ^ and 7.5 months^ 78 ^ in the three U.S. studies. In the Whipps Cross study,^ 83 ^ performed in the United Kingdom, the mean age at amplification was 4.2 months for children who had profound hearing loss and 13.8 months for children who had moderate hearing loss. None of these estimates included children who, although screened, did not return for followup testing or treatment (that is, they were not calculated on the appropriate intention-to-treat basis). None of the studies reported information about the technical success of fitting, including how often the hearing aids were used.

The ages of diagnosis in the screening studies were all considerably earlier than those reported in a national survey.^ 10 ^ The validity of this comparisons is limited, however, because the average ages at detection and amplification exclude cases that might have escaped detection because they were not screened or failed to follow up an abnormal screening test result (ie, they were not calculated on the appropriate intention-to-treat basis). These cases are included in estimates of the time lags in usual care, which are assessed retrospectively and therefore include children diagnosed at a later date, making it likely that the age at diagnosis will appear better in studies of screening than in surveys of usual care.

The evidence that screening leads to earlier treatment could be strengthened in several ways. National surveys of deaf children indicate that the time lag in diagnosis and treatment is shorter for children with profound hearing loss and longest for those with moderate and mild hearing losses.^ 10 ^ The results reported in studies of screening programs are not directly comparable to the results of surveys because the proportion of patients with profound, severe, moderate, and mild hearing losses are not similar in these groups. The results of the Whipps Cross study,^ 83 ^ illustrate that this effect is a large one and that results for moderate and profound hearing losses should be reported separately.

One study of universal screening reported the proportion of low-risk infants with moderate to severe impairment who were fitted with a hearing aid or enrolled in language programs by 6 months of age.^ 99 ^ The median ages at hearing aid fitting were earlier for those in the well baby nursery than NICU, earlier for not-at-risk infants than for at-risk infants, and earlier for those with severe/profound than mild/moderate losses.

### 3. What are the Potential Adverse Effects of UNHS?

To estimate the net benefit of screening -- benefits minus harms -- it is important to have careful studies of the frequency and seriousness of the adverse effects of screening. For any screening program, false-positive test results may lead to adverse effects. The most serious consequence of a false positive screening test result is a false-positive diagnosis of permanent hearing loss. If treatment is instituted early, a false-positive diagnosis can lead to unnecessary surgery or other treatment in a baby who hears normally.

In the case of newborn hearing screening, the final diagnosis of permanent hearing loss is determined using an extensive audiometric examination by an audiologistusing a combination of otolaryngical and audiological examination, diagnostic ABR, and other physiologic testing. This includes behavioral evaluation at 6 to 9 months which confirms electrophysiological diagnosis. In the Wessex trial, the first audiometric examination was done when the babies were between 8 and 12 weeks of age. Of 158 infants who screened positive, 27 were diagnosed to have permanent SNHL; in 2 of these cases (7.4%), however, the diagnosis was wrong, and the babies proved to have normal hearing when re-examined at 4 months or 10 months of age.^ 96 ^

Detailed information about the process of establishing the final diagnosis of permanent SNHL is lacking. None of the studies in Table 2 reported how often a definitive diagnosis could be made at the first audiometric examination, and how often it was correct.

Other potentially serious adverse effects of screening include parental misunderstanding and anxiety, and unfavorable labeling. For newborn hearing screening, even a small increased risk of these effects could have a large impact on the net benefit of a screening program. This is because for low-risk infants there are up to 40 false positives for each true case of hearing impairment, and because up to 10 of these false positives do not return for followup, where definitive testing and interviews with health professionals might allay concerns about the baby's health. No study has attempted to assess directly the effect of a false-positive test result on the parent-infant relationship.

In the Wessex trial, an indirect measure was made in a survey of parents' anxiety and attitudes toward the baby 2 to 12 months after screening.^ 96 ^ On average, parents whose babies were screened had similar anxiety and attitudes to parents in the unscreened group. It should be noted, however, that, before screening was done, the parents in the screened group received information about the benefits of early identification and gave informed consent for the procedure.

A survey of parents whose children participated in a UNHS program at Whipps Cross hospital in the United Kingdom indicated that 97% of the mothers felt that infant screening was beneficial and 1% reported being very worried about the testing. Among the group of parents whose infants failed the initial screening and received a second test, 3.5% (2/57) of parents reported they were very worried; satisfaction with the testing remained high.^ 94 ^

Clemens surveyed 49 mothers of non-NICU infants who failed hospital screening and received a second stage outpatient automated or diagnostic ABR screening test. Two children required additional testing before being diagnosed as hearing normally. Eight percent of mothers (4/49) said they treated their child differently (eg, spoke louder or clapped their hands). Fourteen percent (7/49) reported “lasting anxiety” after the second screening exam. Ninety-four percent (46/49) of the parents of these “false positive” infants approved of UNHS.^ 85 ^ In a survey at a regional hospital in Logan, Utah (n=169), parents indicated acceptance of newborn screening for their infants, 98.2% of parents said they would give permission for screening, 95.3% would prefer screening even if the baby failed, and 84.9% felt that anxiety caused by failing a screening test would be outweighed by the benefits of early detection.^ 95 ^

### 4. Does Screening and Early Treatment Improve Language and Communication Skills?

No prospective, controlled study directly examined whether newborn hearing screening results in improved speech, language, or educational development. None of the demonstrations of screening described in Table 2 reported the outcomes of treatment for infants identified to have hearing impairment

One cohort study compared language performance in hearing-impaired children who were detected by UNHS to those of an unscreened group (see Evidence Table 1).^ 87 ^ All subjects in the study were participants in the Colorado Home Intervention Program (CHIP), a multifaceted program that includes fitting for hearing aids and emphasizes home visits and training parents to be involved in helping their deaf child.^103, 104^ Lists of participating children were given to the director of the Colorado Newborn Hearing Screening Program, who determined whether the children were born after 1996 in a hospital that employed universal screening and did not have significant cognitive delays. A group of non-screened children born since 1992 (n=25) were selected from hospitals without a universal newborn screening program, after matching on degree of hearing loss (mild, moderate, moderately-severe, profound), cognitive quotient, and age at time of speech and language evaluations. The 2 groups were similar in gender, ethnicity, presence of multiple disabilities, mode of communication, education of primary caregiver, and chronological age.

Language skills were measured using a validated instrument, the Minnesota Child Development Inventory, and measuring vocabulary words used during a videotaped child-parent interaction. When the expressive vocabulary of the screened group and the non-screened group were separately divided into percentiles, some striking findings emerged. The children at the 25^th^ percentile in the screened group had more words (80) than the 75^th^ percentile in the non-screened group (50 words). At the 75^th^ percentile the screened group of children had over 500 words compared to only 50 words for the 75^th^ percentile of non-screened children.

Mean scores for expressive, receptive, and total language were within normal range for screened group and 18 to 21 points higher (p<.001) than the unscreened group, whose scores indicated language delay (expressive language 82.9 [SE 3.7] vs. 62.1 [SE 4.3]; receptive language 81.5 [SE 3.7] vs. 66.8 [SE 4.0]; total language 82.2 [SE 3.3] vs. 64.4 [SE 3.9]). Children identified prior to 6 months (whether in the screened or unscreened group) had a smaller gap between language development and cognitive ability. Language development (total language quotient) was within normal range for 56% of the screened group compared to 24% of the unscreened group. Delayed language development (<70) was present in 24% of the screened group compared to 68% of the unscreened group.

This study has important strengths and weaknesses. The study is important primarily because is the only one that compared the language outcomes of a screened group to that of an unscreened group of patients with congenital hearing loss. The main strengths of the study were that it used relevant, validated measures of language outcomes, controlled for several important potential confounders, and applied the equivalent of an “intention-to-treat” analysis. Using the USPSTF grading system (Appendix 3), however, the study received an overall grade of “poor.” The methodologic weaknesses of the study were that assessment of outcomes was not blinded (the examiner could have known whether or not the patient had been detected by screening); the selection of cases was not clearly masked (the director of the screening program may have known the language outcomes when determining who was eligible for the study);and long-term language outcomes and school performance were not measured. Because the screened and unscreened groups were drawn from different hospitals and time periods, it is also possible that the quality of care (not just the timing) provided to the screened group was better than that of the unscreened group.

The study also did not assemble a complete inception cohort of newly-identified patients, a serious flaw that could introduce substantial bias in the results. Ideally, all patients who were diagnosed in a screening hospital and all patients born in nonscreening hospitals would be eligible for inclusion in the study. In this study, eligibility was determined by the availability of an assessment of language outcomes at 2 to 4 years of age, and cases were selected from participants in CHIP rather than from the entire screened and unscreened populations. As noted by the study authors, the database used in this study does not include children who have congenital hearing loss who did not participate and remain available for followup in CHIP. The proportion of dropouts was not recorded, but could have been measured. Because the unscreened group was diagnosed at later ages, they had less time to benefit from the program or to disenroll than the screened, early-identified group. It is possible that the subgroup of screened patients who remained available for followup at 2 to 4 years of age had a better experience with the program and better outcomes than the full cohort of children diagnosed by screening.

Finally, it is not clear from the study how many of the screened and unscreened subjects are members of the group targeted by UNHS -- low-risk infants who would not be diagnosed early by high-risk screening. Moreover, the lack of an inception cohort makes it impossible to determine whether the subjects are representative of this target group.

#### Studies of preschool children who were identified early or late

Current theory views auditory stimuli during the first 6 months of life as critical to development of speech and language skills.^11-13^ This is a critical assumption: if treatment begun at 1 or 2 years of age is as effective as treatment after 6 months, then selective screening of newborns, supplemented by vigilance and appropriate testing if there is parental suspicion, could in theory be as effective as universal screening. (Alternatively, selective screening of newborns could be supplemented by screening of low-risk infants at 7 to 12 months of age.) However, only universal screening can ensure that treatment begins as early as 6 months of age.

Older studies comparing early-identified to late-identified children with impaired hearing consisted of clinical series or case-control studies of highly selected patients, with heterogeneous causes of hearing loss, incompletely defined treatment regimens, and inadequate control for potential confounders.^ 19 ^ Moreover, these studies are outdated because they classified children diagnosed as late as 3 years of age to be “early-identified.”^ 8 ^ The results of these studies were inconsistent, some supporting and some not supporting the hypothesis that early treatment was associated with better language outcomes. None of these older studies examined the outcome of delayed diagnosis in children who have no risk factors for hearing impairment at birth.

Seven recent cohort studies from 3 programs compared language outcomes for early-identified and late-identified infants (Table 3, Evidence Table 1).^27, 88-93^ All of these studies used standardized receptive and expressive tests to evaluate speech and language skills in preschool children, and all reported statistically significant associations between the age at the time of diagnosis and language development at 2 to 5 years of age. Adjusted mean scores for expressive and receptive language were 15 to 20 points higher in groups of children identified and treated early compared to the later identified groups. Although all studies used multivariate analyses, the study populations were composed of convenience samples.

Table 3.Cohort studies reporting language outcomes

Study, Year | Selection of Subjects | Comparability and Maintenance of Early vs. Late Groups | Adjustment for Confounders | Results
Studies from Colorado Home Intervention Program (CHIP)
Apuzzo, 1995^ 90 ^ | Convenience sample of 69 high-risk infants diagnosed between 2 and 25 months of age. Children with severe cognitive delay were excluded. | Late-identified group was more likely to have severe-profound hearing loss (65% vs. 50%). No report of attrition or followup rates. | One-way ANOVA did not adjust for SES, family involvement, or other potential confounders. | At 40 months of age, infants identified before 2 months of age had higher mean Minnesota Child Development Inventory (MCDI) scores for expressive language (p<0.01)
Yoshinaga-Itano, 1998^ 89 ^ | Convenience sample of 40 high-risk infants, divided into those identified and treated before 6 months of age (n=15) and those treated after 18 months (n=25). Children with severe cognitive delay were excluded (DQ<60). | Late-identified group was more likely to have severe to profound hearing loss, ( 52% vs 47%). No report of attrition or followup rates. | Gender, severity of hearing loss, cognitive function, and other disabilities were examined in 2-way ANCOVAs, not in a multiple regression (no simultaneous adjustment for multiple confounders). | At 40 months, infants identified before 6 months of age had better adjusted mean MCDI scores for expressive language (81.1 vs 64.3, p<0.05 ) and receptive language (84.4 vs. 70.1, p<0.05)
Yoshinaga-Itano, 1998^ 27 ^ | Convenience sample of 82 infants, 19 to 36 months of age with mild to profound SNHL, divided into those identified before 6 months of age (n=34) and between 7-18 months of age (n=48). Early group identified by HRR; late group by usual care. Children with severe cognitive delay were excluded (DQ<60). | Late identified group was more likely to have severe to profound hearing loss, (77% vs 42%). No report of attrition or followup rates. | Gender, severity of hearing loss, cognitive function, and other disabilities were examined in 2-way ANCOVAs, not in a multiple regression (no simultaneous adjustment for multiple confounders). | At 26 months, infants identified before 6 months of age had better adjusted mean MCDI scores for expressive language (76.2 vs 56.6, p=0.001), receptive language (82.1 vs 58.3, p=0.002), MacArthur CDI adjusted mean receptive vocabulary (200 vs 86.4, p<0.001), expressive vocabulary (117 vs 54, p<0.03)
Yoshinaga-Itano, 1998^ 88 ^ | Convenience sample of 150 children 13 to 36 months of age with mild to profound SNHL, divided into those identified before (n=72) or after (n=78) 6 months of age. The number of low-risk infants and the role of UNHS in identifying subjects are not described. Selection bias is likely because the design probably excluded infants diagnosed to have hearing loss but did not enter the program, or entered, but were lost to followup. | At baseline, compared groups differed in some demographic characteristics and in the proportion of subjects with cognitive impairment and severe & profound HL.(CQ <80, 29% early group vs. 56%, late group). Severe & profound HL 34% early group vs 46% late group. No report of attrition or followup rates. | There was stratification by cognitive quotient (<80 vs. >80). Other covariates (gender, minority status, maternal education level, Medicaid status, severity, mode of communication, other disabilities) were examined singly in 2-way ANCOVAs. | At 13-36 months, adjusted mean MCDI receptive language quotient (LQ) was higher for those identified before 6 months (79.6 vs. 64.6, p<0.001). Mean MCDI expressive LQ was higher (78.3 vs 63.1, p<0.001) as well as total language (79 vs 64, p<0.001) higher in early identified group . No difference in LQs between 4 age of identification levels in late group.
Mayne, 2000^ 92 ^ | Convenience sample of 113 children 24-37 months of age, divided into those diagnosed before and after 6 months of age. The number of low-risk infants and the role of UNHS in identifying subjects are not described. Overlap of sample with previous CHIP studies was not reported. | Demographic comparisons of the groups were not reported. No report of attrition or followup rates. | Regression analysis adjusted for degree of hearing loss, mode of communication, other disabilities, parents' hearing, cognitive quotient, mother's education, ethnicity, SES | At 24-36 months, age at diagnosis explained 23% of the variance in expressive language scores.
Studies from other programs
Moeller, 2000^ 91 ^ | Convenience sample of 112 5 year olds who completed the Diagnostic Early Intervention Program in Lincoln, Nebraska. Children with non-verbal IQ <70 and those who did not participate in program through age 5 were excluded. The number of low-risk infants and the role of UNHS in identifying subjects are not described. Outcome assessments were made pre- and post-intervention. | Not reported. No report of attrition or followup rates. Early identified children may have more opportunity to drop out, although differential drop out may be less of a problem at 5 years than in studies assessing closer to enrollment. | Multiple regression analysis adjusted for family involvement, degree of hearing loss and non-verbal IQ. | At age 5, family involvement accounted for 57% of variance in vocabulary and age of enrollment accounted for 11.5%. Adjusted mean vocabulary and reasoning scores were within normal range among children enrolled prior to 11 months but were lower for later-identified children.
Calderon, 2000^ 93 ^ | Cohort of 80 children with profound hearing loss enrolled in Early Child Hearing Intervention (ECHI) in Seattle Washington. Children with developmental delay were excluded. Cohort grouped by 3 levels by age of entry into program: <1 year (n=9), 12-24 months (n=39), >24 months (n=32). The method of sampling is not described, but the design excluded patients who entered the program but did not graduate. | Not reported. Late diagnosed group had less severe-to-profound loss (36% vs. 66%). Overall loss to followup not reported. Because the early-diagnosed group were in the program longer, they had more opportunity to drop out, so a differential loss to followup is likely. | Controlled for degree of hearing loss, degree of outcome impairment that was present upon entry into program (baseline test levels). | At 3 years, age at entry to program explained 43.5% of the variance in receptive language and 49% of the variance in expressive language. Children treated before 2 years had better outcomes than those treated after 2 years. Only 3 children entered the program prior to 6 months of age.

Evidence Table 2 (Quality ratings) summarizes methodologic aspects of these studies. One problem with all of these observational studies is that other confounding factors (that is, factors other than screening and early treatment) may be associated with early diagnosis and with better language outcomes. For example, the early-treated group may have benefited from better family involvement and knowledge or access to better hospitals and providers.

Another problem is that all of these studies report an intermediate outcome -- language development in preschool age -- rather than the outcomes of primary interest, namely communication, and social, educational, and occupational function later in childhood and in adulthood.

A third problem is that none of them focus on the population of interest -- children who would be identified by UNHS but who would escape detection using selective high-risk screening. A fourth characteristic is that none of the studies related specific treatments to outcomes, so it is possible that the differences in language achievement reflect the impact of a single component of the intervention rather than that of a comprehensive treatment plan.

Five studies reported speech and language results for children enrolled in CHIP.^27, 88-90, 92^ The most widely cited of these studies compared 72 hearing-impaired children identified prior to 6 months of age to 78 hearing impaired children identified after 6 months.^ 88 ^ These children were identified from the CHIP database. (It is not clear whether the subjects overlap with those of the Yoshinaga-Itano 2000 study^ 87 ^ described above.) After adjustment for cognitive function, children whose hearing losses were identified by 6 months of age demonstrated significantly better receptive, expressive, and total language scores than children identified after 6 months of age. For children with normal cognitive abilities, this language advantage was found across all test ages, communication modes, degree of hearing loss, and socioeconomic strata. Children (with normal cognitive abilities) identified early had language scores at or near their cognitive test scores, whereas children identified after 6 months of age performed, on average, 20 points lower on language scores than cognitive scores. For infants identified and treated by 6 months of age, there was a 20-point-higher mean language quotient in children with normal cognitive quotients compared to infants identified after 6 months (92.2 vs. 71.7[receptive] and 90.5 vs. 68.7 [expressive]). A language quotient of 100 represents functioning at an age-appropriate level; a child with language quotient of 90 is functioning at a level of 90 percent of his/her chronological age. A score of 70.2 means that a 24-month-old communicates at the level of a 17-month-old child, while the language of a 36-month-old resembles that of a 25-month-old. These differences are clinically significant: at 17 to 18 months, a typically developing child has a productive vocabulary of about 50 words and uses few 2-word phrases. At 24 months, a typically developing child has a productive vocabulary of 250 to 300 words (5-6 times the vocabulary he/she had 6 months earlier) and regularly produces sentences of 3 to 5 words. By 36 months, a typically developing child has a vocabulary of over 1000 words. Thus, the child with a language quotient of 70.2 lags 6 months behind peers at 24 months and a year behind at 36 months. The 20-point gap is more than 1 standard deviation lower than normal for age, which would indicate that a child with normal intellect would have the language abilities of a child who had an IQ of 80. Children with low cognitive abilities (cognitive quotient <80), experienced a smaller improvement; the later-identified group had a mean gap between cognitive quotient and language quotient of 10 points. For this group the total language difference was significant (p=.05), while receptive and expressive language differences were not significant (p=.06, .09).

The main strengths of the study were that it used relevant, validated measures of language outcomes and controlled for several important potential confounders. The study also has important weaknesses and was rated “poor” using the USPSTF system (Appendix 3). The most important weakness is that the 2 groups -- those diagnosed before 6 months and those diagnosed after 6 months -- were dissimilar. Patients in the late-identified group were more likely to be cognitively impaired (56% vs. 29%, p<0.001), to have severe or worse hearing loss (46% vs. 34%, NS), and to use sign language (54% vs. 46%, NS); their mothers were less likely to have finished high school (52% did not vs. 43%, NS). Language ability was assessed at a later age in the late-identified children than in the early-identified children (56% after 24 months vs. 44% earlier, p=0.03). The statistical adjustment used in the analysis did not simultaneously adjust for more than 2 factors and may not have removed the influence of these differences. The data provided in the study were inadequate to determine how much attrition occurred prior to the assessments, and the assessments were not masked.

Additional evidence for the effect of early identification and treatment was provided by a cohort study of 112 children continuously enrolled in a diagnostic early intervention program in Nebraska.^ 91 ^ It found that after adjustment for family involvement, degree of hearing loss, and nonverbal IQ, children enrolled prior to 11 months had stronger vocabulary and reasoning skills than children enrolled at later ages. The study demonstrated that early identification was related to vocabulary at age 5, but accounted for much less of the variance than family involvement. At age 5, family involvement accounted for 57% of variance in vocabulary, and age of enrollment accounted for 11.5%.

The remaining studies also used multiple regression, but did not adjust for family involvement. For this reason, these studies probably overestimated the association of early enrollment with language development. In one, a retrospective series of 80 children in a home intervention program in Washington State,^ 93 ^ early enrollment was associated with better language skills at 3 years of age. The relevance to newborn screening is low because only 9 subjects were enrolled before 12 months of age. Mayne and colleagues evaluated factors related to expressive language development in a group of 113 deaf and hard-of-hearing children enrolled in the CHIP program.^ 92 ^ They reported that expressive vocabulary was higher with increased age, increased cognitive quotient, identification of hearing loss by the age of 6 months, and having a hearing loss as the only medical condition. The full regression model explained 56% of variance in expressive vocabulary scores.

The studies in Table 3 had several important limitations. The study populations were composed of convenience samples. That is, the studies compared children who were identified early and late by means other than UNHS, rather than children whose age at identification and enrollment was determined primarily by whether or not they were screened. None of the studies had clear criteria for inclusion, none had blinded assessments, and all selected children for inclusion based on the availability of a language assessment between ages 2 to 5. This could introduce bias: early-identified children who remained in the program may have had better results than early-identified children who were not available for followup. Because of these limitations, selection bias cannot be confidently ruled out as an explanation for the findings. Moeller found family involvement an important contributor to language development. Since other studies did not adjust for this factor, they may have overestimated the association of early enrollment with language development. None of the studies provides information on attrition or follow up rates.

### 5. What are the Potential Adverse Effects of Early Treatment?

The harms of early treatment have not been adequately studied. As noted by the 2^nd^ USPSTF,^ 19 ^ differing ethical and philosophical attitudes about deaf awareness and culture have led to controversy about the content of early interventions. The argument for early intervention is based on the prevailing theory of language development, which holds that early auditory input is an important precursor of language development. An opposing viewpoint that has been expressed in the literature is that, during infancy, nonverbal communication, joint attention, shared experiences, and mutual understanding are more important precursors of language development than hearing speech and forming sounds. From this viewpoint, early intervention could be harmful, as expressed in this excerpt from a review article:

“there is a risk that if a hearing impairment is detected early and if the parents are recommended to focus on means of communication that the child has the least prerequisites for, the interaction will be altered and gradually impeded. The parents will start to look upon their child as someone with a functional disability, not as a baby with unique competences and possibilities.”^ 105 ^

Because there are no randomized trials of different management strategies, it is impossible to assess the merits of these concerns. While the studies reviewed above provide no evidence for this hypothesis, they were not adequately designed to detect a harm if one were present. A review of the theoretical literature underlying different attitudes about the treatment of hearing impairment is beyond the scope of this review.