# Methods

## A. Literature Search

Before we arrived at the final key questions listed in Figure 2, we considered a longer list of questions that potentially could have been answered in a literature review. This list included more specific questions about the consequences of screening and questions about benefits of treatment other than language skills and school performance. We conducted a preliminary MEDLINE search to eliminate questions for which we were unable to find evidence. For example, we did not find studies that evaluated the significance of poor communication skills on social functioning and occupational opportunities, so our outcome measures are limited to language and communication skills during early childhood in the final list of key questions.

To find relevant articles on screening for hearing impairment, we searched the MEDLINE, CINAHL, and PsycINFO databases for papers published from 1994 to September 2000. (See Appendix 1 for the MEDLINE search string.) We also used reference lists of comprehensive review articles^8, 21, 45-53^ and expert recommendations to locate additional articles published after 1994. We relied on the 1995 USPSTF's review^ 19 ^ and suggestions of experts and peer reviewers to identify important articles published in 1994 or earlier. Searches were updated monthly through August 2001.

Searches of the electronic databases returned 864 abstracts. Two investigators reviewed each abstract to determine whether to obtain the full text of the article. Disagreement was resolved by discussion. Abstracts were included if both reviewers agreed that the topic was relevant to one of the key questions and the article contained data. Abstracts were also included if there was not sufficient information to classify the article. The full-text versions of 177 articles from the searches and about 30 articles from other sources were obtained and examined by 2 reviewers for inclusion in evidence tables.

Full-text articles were included in the systematic review if they were 1) controlled trials, 2) reports on the accuracy, yield, or harms of screening from state-based, population-based studies, or hospital-based UNHS programs using ABR or OAE technology in the general newborn population, or 3) reports of the effects of screening, early identification and treatment, or any type of language outcomes. For the last group, we excluded uncontrolled case series and case reports. ^54-62^ We excluded studies in which screening was done with physical examination or with tests other than ABR or OAE.^37, 63-77^ We also included studies that reported any information about the adverse effects of screening or early diagnosis, but did not attempt to review the adverse effects of hearing aids and cochlear implants. Search results are listed in Appendix 2.

## B. Literature Synthesis and Preparation of the Systematic Evidence Review

Twenty-two articles met these inclusion criteria and were abstracted using a standard electronic spreadsheet. From each of the 10 included screening studies (Figure 1, Arrows 1 and 2),^14, 71, 78-85^ we abstracted the following information: year of publication, study design (randomized controlled trial, cohort, case-control, controlled case series, or time series comparisons), characteristics of patients studied (risk status, degree and type of hearing loss, age at testing), screening protocol (test used, pass criteria, followup screening and diagnostic testing), years of data collection, number of patients screened, number with a positive screening test, method used to make the final diagnosis and the age at which it was done, number with confirmed SNHL, age at diagnosis, referrals, compliance with referrals, and age at amplification. We calculated the number of patients with a final diagnosis of bilateral SNHL divided by the number of neonates screened and its inverse, the number needed to screen (NNS) to identify one infant with bilateral SNHL. Where possible, we calculated the NNS in high-risk infants, who would likely be identified by high-risk screening strategies already in place, compared with low-risk infants, who would be identified early only by UNHS. When the information was available we also calculated the NNS for the subset of patients who had complete followup.

For studies of the accuracy of screening tests, we defined sensitivity as the number of infants with hearing loss who screened positive divided by the actual number of infants with hearing loss. We defined specificity as the number of infants with normal hearing who screened negative divided by the total number of infants with normal hearing. We also calculated the positive predictive value as the number of infants with hearing loss who screened positive and later proved to have permanent bilateral SNHL divided by the number of infants who screened positive. The number and type of screening tests administered, and the criteria used to define a positive test, varied among the studies. In most programs, for example, the in-hospital phase of testing had 2 stages (eg, an OAE followed by an ABR, or an ABR repeated once), but other protocols used a single stage (e.g, one OAE or ABR). To be consistent across studies, we defined a screen as positive if, based on whatever tests were done by the time of discharge from the hospital, a referral for repeat testing or audiologic consultation would be recommended.

In most screening methodologies, the gold standard allows for validating the screening tool immediately, in the case of hearing, the accuracy of the gold standard, behavioral and/or audiologic evaluation, depends on the age at which it is performed. Moreover, in the months after discharge from the hospital, audiologic evaluation might be repeated several times before a definitive diagnosis can be made. With input from the Task Force, we defined tests performed in the hospital during the birth admission as “screening” tests, and defined subsequent testing performed as part of an effort to establish the final diagnosis to be part of the followup evaluation.

It is possible that some cases of hearing loss could develop in the months between birth screening and the gold standard evaluation. As is done for other conditions, for example, Pap smears for cervical cancer and mammography for breast cancer, we classified these as “biological false-negative” results.^ 86 ^

For the 8 studies evaluating the effect of screening or early treatment on speech and language outcomes (Figure 1, Arrow 4),^87-93^ we abstracted the following information: year of publication, study design, years of data collection, characteristics of patients studied (risk status, degree and type of hearing loss, age at testing, sociodemographic information, family characteristics, cognitive ability), definition of hearing impairment, type of treatment program, and specific tests used to measure receptive and expressive language development, as well as the test scores. Three surveys^85, 94, 95^ and one chart review study^ 96 ^ provided information on adverse effects of early diagnosis and treatment (Figure 1, Arrow 5). We used the USPSTF criteria for grading the quality of studies (Appendix 3) to select the methodologically strongest studies, and to grade the overall evidence for each link in the analytic framework. Study quality is discussed in detail in the Results section.

We constructed a mathematical model of the likely benefits and harms of screening 10,000 newborns. We used the results of the literature review to estimate prevalence, sensitivity and specificity, compliance, treatment effect size, and other parameters of the model.