# Introduction

Each year in the United States, approximately 5000 infants are born with moderate, severe, or profound bilateral sensorineural hearing loss (SNHL). Hearing loss in childhood is associated with poor language development in early childhood and with lower educational achievement and employment opportunities later in life.^1-5^

For children without risk factors, hearing loss frequently escapes detection until the age when hearing children normally begin to talk (at 9 months of age or older).^6-10^ Current theory views auditory stimuli during the first 6 months of life as critical to development of speech and language skills.^11-13^ Advocates of universal newborn hearing screening (UNHS) believe that earlier application of available therapies, such as speech and language therapy, amplification, and family support, could reduce or eliminate the gap in language skills between deaf and hearing children.^14, 15^ Screening in the hospital prior to discharge also presents an opportunity to provide services to children with limited access to routine medical care, and is one way to deliver state-of-the-art services to disadvantaged and under-served populations.

The incidence of SNHL varies with race, birthweight, and other risk factors. Among infants in a neonatal intensive care unit (NICU), the risk of moderate to severe SNHL is 10 to 20 times higher than the general population.^ 16 ^ The Joint Committee on Infant Hearing high risk guidelines specify admission of 2 or more days to an NICU or one of 4 other risk factors (Table 1).^ 17 ^ From 10% to 30% of newborns meet these criteria, which can identify 50% to 75% of all cases of moderate to profound bilateral hearing loss.^ 18 ^

Table 1. Risk factors for sensorineural hearing loss in newborns.*

1. NICU admission for 2 or more days
2. Usher's Syndrome, Waardenburg's Syndrome, or findings associated with other syndromes known to includehearing loss
3. Family history of hereditary childhood sensorineural hearing loss
4. Congenital infections such as toxoplasmosis, bacterial meningitis, syphilis, rubella, cytomegalovirus, and herpes
5. Craniofacial anomalies, including morphologic abnormalities of the pinna and earcanal

*Joint Committee on Infant Hearing criteria foridentifying infants at high risk for hearing loss.^ 17 ^

In 1995 the US Preventive Services Task Force (USPSTF) found insufficient evidence to recommend UNHS.^ 19 ^ They argued that, among low-risk infants, the prevalence of hearing impairment was very low, and substantial numbers of infants would be misclassified. They found that evidence for the efficacy of early intervention for patients diagnosed by screening was incomplete, but endorsed selective screening of high-risk newborns based on the higher prevalence of hearing loss in this group.

Since 1995, many health care professionals and federal health care agencies have advocated for UNHS, which is now mandated by law in 32 states.^6, 17, 20^ Is this widespread support for UNHS now justified? To update the USPSTF recommendations, we critically reviewed recent evidence to identify strengths, weaknesses, and gaps in the evidence supporting UNHS.

## A. Epidemiology and Burden of Illness

Estimates of the prevalence of moderate to profound bilateral hearing loss vary, depending on the criteria used to define the different degrees of hearing loss and the characteristics of the studied population.^ 21 ^ When a criterion of > 40 dB HL is used to diagnose moderate hearing loss, the prevalence of permanent, congenital bilateral hearing loss ranges from 1 in 900 to 1 in 2,500 newborns.^18, 22-26^ From one-third to two-thirds of these have moderate bilateral hearing loss, while the remainder have severe or profound hearing loss.

The prevalence of congenital hearing loss also depends on race, birthweight, and other risk factors. In a well-done, population-based survey of 3-year olds in Atlanta, Georgia, the overall prevalence of congenital bilateral hearing loss was 1 in 2400 in whites and 1 in 1350 in blacks.^ 26 ^ Among low birthweight infants (<2500 grams), 1 in 500 black children and 1 in 714 white children had bilateral hearing loss. Among infants admitted to an intensive care unit, the risk of moderate to severe SNHL is 10 to 20 times as high as the healthy nursery population. In the Rhode Island Hearing Assessment Project, for example, 1 in 76 newborns had hearing impairment in the intensive care population, versus 1 in 775 in the well-baby nursery.^ 16 ^ The prevalence is lower still in the subset of well infants who have no family history of hearing impairment.

It is clear that the diagnosis of congenital hearing impairment is often delayed. A British study found that 19% of children with congenital hearing loss were identified by the age of 6 months and 39% by their first year.^ 7 ^ It is thought that, in the United Kingdom, about a quarter of children remain undiagnosed until after 42 months of age.^ 8 ^ In 1993, a National Institutes of Health panel estimated that the average age of identification in the US was about 3 years.^ 6 ^ In a survey of 331 parents from 35 states,^ 10 ^ performed in the early 1990s, the median age at diagnosis was 12.5 months for all children with severe and profound congenital hearing loss and 17.2 months for all children with mild and moderate losses. For children with no known risk factors for hearing loss, the median age of diagnosis was 13 months for those with severe to profound hearing loss and 22 months for children with mild-moderate hearing loss. In a more recent survey conducted by the Center for Assessment and Demographic Studies at Gallaudet University, the mean age of diagnosis of deaf children was 14.5 months.^ 9 ^

On average, children with hearing loss have delayed development in vocabulary, grammar, conversation, and reading.^1-5^ This delay is measurable before 3 years of age^ 27 ^ and has consequences throughout life. The 1997-98 Gallaudet Research Institute's annual survey of deaf and hard-of-hearing children and youth nationwide (n=30,198) found that half of the students had communication limitations, and almost half had at least one cognitive, behavioral, or social limitation.^ 28 ^ The average deaf student graduates from high school with language and academic achievement levels below those of the average fourth-grade student with normal hearing.^29, 30^ Average reading scores for hard-of-hearing students graduating from high school are at the fifth-grade level.^29, 31^ The lag in reading performance has remained virtually unchanged since it was first carefully measured in the early 1960s.^32, 33^

The contribution of delayed identification to this lag in communication is difficult to assess. One-third to one-half of infants with congenital hearing impairment have other developmental disabilities, most often mental retardation and sequelae of prematurity, that contribute to poor language development. The degree of parental involvement and the availability of special educational facilities, which may also contribute to language outcomes, are not controlled for in most frequently cited studies of the development of language skills.

In fact, the natural history of congenital hearing loss in the subgroup that is the primary target of universal screening has not been studied carefully. The studies that establish that hearing impairment has serious consequences do not focus on the subset of children who have no risk factors for congenital hearing loss. This group, which is comprised of children who did not require NICU admission and do not have other risk factors for hearing impairment, may have a lower prevalence of coexisting disabilities than do hearing impaired children in general. The frequency, severity, and, especially, the duration of language delay throughout childhood and into adult life in this group is not known.

Screening also detects mild, fluctuating, and unilateral SNHL, as well as conductive hearing loss. These conditions are common in school-age children and clearly delay speech and language acquisition and harm school performance.^34-36^ Very little information is available about how often mild impairment detected at birth proves to be temporary or indistinguishable from normal in followup testing. Many studies address the consequences of mild and unilateral hearing loss that is acquired after infancy, but the frequency and significance of these conditions detected at birth is not clear.

## B. Health Care Interventions

### Screening Tests

Two types of tests are commonly used to screen for congenital hearing loss: otoacoustic emissions (OAEs) and auditory brainstem response (ABR). OAE testing evaluates the integrity of the inner ear (cochlea). In response to noise, vibrations of the hair cells in a healthy inner ear generate electrical responses, known as otoacoustic emissions. The absence of OAEs indicates that the inner ear is not responding appropriately to sound. Transient evoked otoacoustic emissions (TEOAEs) are generated in response to wide-band clicks, while distortion product otoacoustic emissions (DPOAE) are a response to tones. Both stimuli are presented via a light-weight ear canal probe. A microphone picks up the signal, and multiple responses are averaged to get a specific repeatable waveform.

The ABR is an electrophysiological response generated in the brainstem in response to auditory signals and composed of either clicks or tones. The stimulus is delivered via earphones or an inserted ear probe, and scalp electrodes pick up the signal. ABR evaluates the integrity of the peripheral auditory system and the auditory nerve pathways up to the brainstem and is able to identify infants with normal cochlear function but abnormal eighth-nerve function (auditory neuropathy).

Typically, screening programs use a 2-stage screening approach (either OAE repeated twice, OAE followed by ABR, or ABR repeated twice). Criteria for defining a “pass” or “fail” on the initial screening test vary widely. In a survey of 25 programs, for example, 21 different “pass” criteria were being used.^ 37 ^

ABR and OAE have limitations that affect their accuracy in certain patients. Both require a sleeping or quiet child. Middle-ear effusion or debris in the external canal can compromise the accuracy of these tests. OAE and ABR test the peripheral auditory system and eighth nerve pathway to the brainstem, respectively. They are not designed to identify infants with central hearing deficits. Therefore, infants with risk factors for central hearing deficits, particularly those who have congenital Cytomegalovirus infection or prolonged severe hypoxia at birth, may pass their newborn hearing screens with either OAE or ABR, but develop profound hearing loss in early infancy.^38, 39^

The newer generation of automated screeners are easy to use and do not require highly trained staff. However, equipping hospitals with equipment and sufficient staff can be costly, the staff must be trained to understand the limitations of the techniques, and ongoing quality control is essential to achieve accurate, consistent test results. The importance of technique is illustrated by the results of multicenter studies of universal screening, in which the rates of false positive and technically inadequate examinations varied ten-fold among sites.^ 40 ^

### Confirmation of the Final Diagnosis

A behavioral test, such as visual reinforcement audiometry (VRA), is the appropriate gold standard determination for permanent hearing impairment.^ 41 ^ Because VRA cannot be performed reliably before 8 to 9 months of age,^42, 43^ studies of screening use an intermediate diagnostic standard to follow up results of screening tests. The intermediate diagnostic standard usually consists of diagnostic ABR testing or other electrophysiological testing, along with an otolaryngological examination, ^ 43 ^ These assessments have traditionally been performed after 6 months of age, but in some programs are done as early as 2 months of age. The accuracy of the intermediate diagnostic standard depends on the age at which it is performed. The interobserver variability of these assessments in infants has not been evaluated in high-quality studies, and the frequency of over- and under-diagnosis is not known.

### Further Management

A well-defined, well-established treatment protocol of proven effectiveness is often cited as a prerequisite to adoption of a new screening program.^ 17 ^ Management of infants who have hearing impairment is multifaceted, reflecting the complex pathology of poor language development as well as uncertainty about the benefits and risks of alternative treatment plans. Programs for infants and children who have impaired hearing usually include a component of family therapy, intended to prepare parents and siblings to care for and communicate with a deaf child. Hearing aids, cochlear implants, auditory trainers, and communication systems (speech, cued speech, sign language) are also used.^5, 44^

Different experts advocate substantially different approaches based on competing theories of language acquisition and communication. This variation is reflected in practice, even among programs in states or hospitals with established screening programs. In a survey of 500 programs in 15 states, 388 programs indicated that they provide early intervention services.^ 44 ^ The programs varied in their fundamental approach to instruction. About half of the programs offered an Auditory-Verbal approach (emphasizing “the acquisition of spoken language through specific auditory training techniques”), while the other half offered an Auditory-Oral approach (stressing “the use of residual hearing, speech, and oral language development”). Half of the programs offered American Sign Language, and 57% offered an English-based sign system with simultaneous speech. Other high-variation components of care were the methods used to assess progress in children's skills; availability of medical specialists (56%), psychologists (70%), and deaf adults (62%) as consultants or instructors; and the use of parental support groups (51%).

The reason for this variation is that the evidence basis for many components of the intervention is weak.^ 5 ^ The efficacy of early intervention programs for hearing impaired children, and the individual components of these programs, have not been established in randomized trials or in population-based cohort studies.

Practices regarding the timing of interventions also vary. Variation in the timing of treatment could limit the effectiveness of newborn screening. Current theory argues for initiation of treatment before 6 months of age.^11-13^ In one retrospective, population-based study of hearing-impaired children born in Trent, United Kingdom, during the late 1980s, the median age at referral, confirmation of the impairment, prescription of the hearing aid, and fitting of the hearing aid were, respectively, 10.4 months, 18.1 months, 24.4 months and 26.3 months.^ 18 ^ On average, 7.7 months passed between the time a child was referred for audiological examination and the time a final diagnosis was made. It is not clear whether this discrepancy was due to administrative delays, parental decisions, or the need for observation over time to confirm the suspected diagnosis. A lag time of 6.3 months was observed between the time of diagnosis and the time that a hearing aid was prescribed. Survey results from the United States showed a great deal of variation in the lag time between diagnostic confirmation and onset of interventions.^ 9 ^ The average lag times ranged from 8.1 months for hearing aids to 11.2 months for sign language. Lag times were longer for children with milder losses, for those who had deaf parents, and for sign language, Hispanic and black children. However, these factors account for only a small portion of the variation in lag times and do not explain the high lag times observed in children without these factors.

## C. Analytic Framework and Key Questions

The key assumptions underlying UNHS are that 1) diagnosis and, therefore, treatment are delayed until after age 1 or 2 in many of these children; 2) delays result in anxiety and stress on the family and the infant; 3) selective screening of high-risk newborns misses as many as half the cases of moderate to profound hearing impairment; 4) universal screening would reduce the frequency of delay;and 5) early treatment results in better language function in the preschool period, leading to better educational, occupational, and social function later in life.

As noted earlier, solid data support the first assumption, and there is a plausible case, based on anecdotal evidence, for the second. Recent studies of UNHS address the last three assumptions. Figure 1, the analytic framework for this systematic review, depicts assumptions that underlie UNHS in a diagram of the populations, interventions, intermediate outcomes, and health outcomes affected. Available studies of the effects of early intervention focus on the intermediate outcome of language and communication skills in preschool children. The framework notes that, in the long-term, the health outcomes of primary interest might include mental health, psychosocial and cognitive function, and school and occupational performance throughout life. The purpose of our systematic review was to assess whether there was sufficient evidence about each link in the analytic framework to estimate the net effect of universal screening indirectly from separate bodies of evidence about universal screening programs and about alternatives, such as high-risk screening.

Figure 1. Analytic Framework

Figure 2 lists key questions related to each link in the analytic framework. Our search and review of the literature was organized around these questions. To assess how accurately screening can diagnose congenital hearing impairment, we asked questions about the sensitivity and specificity of the OAE and ABR tests and about the yield of screening in actual practice, taking compliance with screening and followup into account (Arrow 1).

Figure 2. Key questions in analytic framework

1. Can UNHS accurately diagnose moderate to severe sensorineural hearing impairment? (Arrow 1)
  - What are the sensitivity and false negative rate of screening tests?
  - What are the specificity, false positive rate, and predictive value of screening tests?
  - Compared to selective screening of high-risk newborns, how many more cases are identified?
  - How much earlier are children diagnosed and treated?
2. What are the potential adverse effects of universal screening? (Arrow 2)
3. Does screening lead to improved language and communication skills? (Arrow 3)
4. Does treatment prior to 6 months lead to improved language and communication in infants who would not be diagnosed that early in a selective, high-risk screening program? (Arrow 4)
5. What are the potential adverse effects of early treatment? (Arrow 5)

Randomized trials or well-done cohort studies would provide the best evidence linking UNHS to improved language outcomes in infants who would not be diagnosed early in a high-risk screening program (Arrow 3). No such studies have been published. Instead, inferences about the effect of early treatment rely on observational studies that examine the association between birth at a hospital where UNHS was practiced, or the age at diagnosis of hearing loss, and language ability in children of preschool age (Arrow 4). The fundamental question is, does treatment prior to 6 months lead to improved language and communication in infants who would not be diagnosed that early in a selective, high-risk screening program? This additional benefit due to screening must outweigh the harms of screening in children who do not have hearing impairment (Arrow 2) and the potential harms, if any, due to early diagnosis and treatment in children who have hearing impairment (Arrow 5).