# Appendix 3. US Preventive Services Task Force Quality Rating

## Randomized Controlled Trials and Cohort Studies

### Criteria

- Initial assembly of comparable groups.
  a. For RCTs: adequate randomization, including first concealment and whether potential confounders were distributed equally among groups.
  b. For cohort studies: consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts.
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination).
- Levels of follow-up: differential loss between groups;overall loss to follow-up
- Measurements: equal, reliable, and valid, and including masking of outcome assessment.
- Clear definition of interventions.
- Important outcomes considered.
- Analysis:
  a. For RCTs: intention-to-treat analysis
  b. For cohort studies: adjustment for potential confounders.

### Definition of ratings based on above criteria

- Good:
- Meets all criteria: comparable groups are assembled initially and maintained throughout the study; follow-up at least 80 percent; reliable and valid measurement instruments applied equally to the groups; interventions clearly defined; important outcomes are considered; and appropriate attention to confounders in analysis. In addition, for RCTs, intention-to-treat analysis is used.
- Fair:
- Generally comparable groups assembled initially but some question remains whether some (although not major) differences occurred in follow-up;measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is done for RCTS.
- Poor:
- Groups assembled initially are not close to being comparable or maintained throughout the study; measurement instruments are unreliable or invalid or not applied at all equally among groups; outcome assessment not masked; and key confounders are given little or no attention. For RCTs, no intention-to-treat analysis.