# Appendix 1. Search Strategy

Set | Search
1 | exp hearing disorders/
2 | infant/or infant, newborn/
3 | 1 and 2
4 | limit 3 to human/
5 | limit 4 to English language/
6 | 4 not 5
7 | limit 6 to abstracts
8 | 5 or 7
9 | exp mass screening/
10 | screen$.tw.
11 | exp hearing tests/
12 | 9 or 10 or 11
13 | 8 and 12
14 | cochlear implants/
15 | exp hearing aids/
16 | exp manual communication/
17 | exp rehabilitation of hearing impaired/
18 | esp hearing disorders/dt,rh,su,th
19 | 14 or 15 or 16 or 17 or 18
20 | 8 and 12
21 | 13 or 20
22 | exp hearing disorders/
23 | limit 22 to human
24 | limit 23 to english language
25 | limit 24 to (preschool child <2 to 5 years> or child <6 to 12 years> or adolescence <13 to 18 years>)
26 | 19 and 25
27 | exp evaluation studies/
28 | follow-up studies/
29 | meta analysis/
30 | exp clinical trials/
31 | 27 or 28 or 29 or 30
32 | 26 and 31
33 | limit 26 to (controlled clinical trial or guideline or meta analysis or mulitcenter study or practice guideline or randomized controlled trial or review, multicase)
34 | 32 or 33
35 | 21 or 34