# Appendix 3. Selected Evidence from the May 2003 AHRQ Evidence Reporta on the Diagnosis and Treatment of Coronary Heart Disease in Women

LIPIDS: CHARACTERISTICS OF CLINICAL TRIALS

Study Name, Year | N Women/Total(% Women) | Mean Age of Women | % with CHD* | Lipid Entry Criterion | Drug | Mean Follow Up (years) | Outcomes in Women | Quality Rating^†^
Scottish Society of Physicians, 1971^1^ | 124/717 (17) | 54 | 100% | None | Clofibrate | 6 | CHD mortality nonfatal MI | Fair
Newcastle Upon Tyne, 1971^2^ | 97/497 (20) | 54 | 100% | None | Clofibrate | 5 | CHD mortality nonfatal MI | Fair
Colestipol Study, 1978^3^ | 1184/2278 (52) | 57 | 20% | TC >250 mg/dl | Colestipol | 3 | total mortality CHD mortality | Fair
4S, 1994^4^–^6^ | 827/4444 (19) | 61 | 100% | TC 213–309 mg/dl | Simvastatin | 5.4 | total mortality CHD mortality nonfatal MI revascularization CHD events^‡^ | Good
ACAPS, 1994^7,^ ^8^ | 441/919 (48) | 61 | 0% | LDL 130–159 mg/dl with any number of risk factors; LDL 160–189 mg/dl with no or one risk factor | Lovastatin | 2.8 | total mortality CHD mortality nonfatal MI | Good
PLAC II, 1994^9^ | 22/151 (15) | NA | 100% | LDL in 60–90th percentile for age and gender | Pravastatin | 3 | total mortality CHD mortality nonfatal MI | Good
CARE, 1998^10^–^12^ | 576/4159 (14) | 61 | 100% | TC <240 mg/dl and LDL-C 115–174 mg/dl | Pravastatin | 5 | total mortality CHD mortality nonfatal MI Revascularization CHD events^‡^ | Good
LIPID, 1998^13^–^15^ | 1516/9014 (17) | 62 | 100% | TC 155–271 mg/dl | Pravastatin | 6.1 | CHD events^‡^ | Good
AFCAPS/TEXCAPS, 1998^16,^ ^17^ | 997/6605 (15) | 62 | 0% | TC 180–264 mg/dl LDL 130–190 mg/dl and HDL <47 mg/dl | Lovastatin | 5.2 | total mortality CHD mortality nonfatal MI revascularization CHD events^‡^ | Good
HPS, 2002^18^ | 5082/20,536 (25) | NA | 65% | TC >135 mg/dl | Simvastatin | 5 | CHD events^‡^ | Good
ALLHAT, 2002^19^ | 5051/10,355 (49) | NA | 14% | LDL 100–189 mg/dl | Pravastatin | 4.8 | total mortality CHD events^‡^ | Fair

a Grady D, Chaput L, Kristof M. Diagnosis and Treatment of Coronary Heart Disease in Women: Systematic Reviews of Evidence on Selected Topics. Evidence Report/Technology Assessment No. 81. (Prepared by the University of California, San Francisco-Stanford Evidence-based Practice Center under Contract No 290-97-0013.) AHRQ Publication No. 03-E037. Rockville, MD: Agency for Healthcare Research and Quality. May 2003.

* CHD defined as history of myocardial infarction or angina.

† See Quality Assessment section in text.

‡ CHD events in CARE, LIPID and ALLHAT defined as CHD mortality or nonfatal MI; in 4S as CHD mortality, non fatal MI or resuscitated cardiac arrest; in AFCAPS as CHD mortality, nonfatal MI or unstable angina or sudden cardiac death; in HPS as CHD mortality, nonfatal MI, stroke or revascularization.

Abbreviations

4S, Scandinavian Simvastatin Survival Study; ACAPS, Asymptomatic Carotid Artery Progression Study; AFCAPS/TEXCAPS, Air Force/Texas Coronary Atherosclerosis Prevention Study; ALLHAT, Antihypertensive and Lipid-Lowering Treatment to Prevent heart Attack Trial; CARE, Cholesterol and Recurrent Events trial; CHD, coronary heart disease; CVD, cardiovascular disease; ; HPS, Heart Protection Study; LDL, low density lipoprotein; LIPID, Long-term Intervention with Pravastatin in Ischemic Disease; mg/dl, milligrams per deciliter; MI, myocardial infarction; N, number; NA, not available; PLAC II, Pravastatin, Lipids and Atherosclerosis in the Carotid Arteries; TC total cholesterol.

LIPIDS: OUTCOMES

Outcome | Study | RR | (95% CI)
Secondary Prevention
Total Mortality | 4S^4^–^6^ PLAC II^9^ | 1.11 1.18 | (0.66, 1.5) (0.03, 54.81)
CHD Mortality | Scottish Society of Physicians^1^ Newcastle Upon Tyne^2^ 4S^4^–^6^ PLAC II^9^ CARE^10^–^12^ | 0.17 0.20 0.79 1.18 0.80 | (0.02, 1.34) (0.04, 1.13) (0.39, 1.6) (0.03, 54.81) (0.61, 1.05)
Nonfatal MI | Scottish Society of Physicians^1^ Newcastle Upon Tyne^2^ 4S^4^–^6^ PLAC II^9^ CARE^10^–^12^ | 0.75 0.43 0.66 1.18 0.51 | 0.42, 1.33) (0.08, 2.25) (0.48, 0.90) (0.48, 54.81) (0.27, 0.94)
CHD events* | 4S^4^–^6^ CARE^10^–^12^ LIPID^13^–^15^ HPS^18^ | 0.68 0.60 0.87 0.81 | (0.51, 0.91) (0.37, 0.97) (0.67, 1.13) (0.72, 0.92)
Revascularization | 4S^4^–^6^ CARE^10^–^12^ | 0.52 0.82 | (0.31, 0.86) (0.64, 1.20)
Primary Prevention
Total Mortality | Colestipol^3^ ACAPS^7,^ ^8^ AFCAPS/TEXCAPS^16,^ ^17^ ALLHAT^19^ | 0.92 0.09 1.53 0.98 | (0.51, 1.69) (0.01, 1.7) (0.62, 3.81) (0.83, 1.17)
CHD Mortality | Colestipol^3^ ACAPS^7,^ ^8^ AFCAPS/TEXCAPS^16,^ ^17^ | 1.08 0.35 2.99 | (0.44, 2.63) (0.01, 8.47) (0.12, 73.3)
Nonfatal MI | ACAPS^7,^ ^8^ AFCAPS/TEXCAPS^16,^ ^17^ | 0.35 0.69 | (0.04, 3.31) (0.21, 2.28)
CHD events* | AFCAPS/TEXCAPS^16,^ ^17^ ALLHAT^19^ | 0.54 1.02 | (0.22, 1.34) (0.81, 1.28)
Revascularization | AFCAPS/TEXCAPS^16,^ ^17^ | 0.87 | (0.33,2.31)

* CHD events in CARE, LIPID and ALLHAT defined as CHD mortality or nonfatal MI; in 4S as CHD mortality, non fatal MI or resuscitated cardiac arrest; in AFCAPS as CHD mortality, nonfatal MI, unstable angina or sudden cardiac death, and in HPS as CHD mortality, nonfatal MI, stroke or revascularization.

Abbreviations

4S, Scandinavian Simvastatin Survival Study; ACAPS, Asymptomatic Carotid Artery Progression Study; AFCAPS/TEXCAPS, Air Force/Texas Coronary Atherosclerosis Prevention Study; ALLHAT, Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial; CARE, Cholesterol and Recurrent Events trial; CHD, coronary heart disease; CI, confidence interval; HPS, Heart Protection Study; LIPID, Long-term Intervention with Pravastatin in Ischaemic Disease; MI, myocardial infarction; NA, not available; PLAC II, Pravastatin, Lipids and Atherosclerosis in the Carotid Arteries; RR, relative risk.

LIPIDS: RESULTS

Outcome | Secondary Prevention | | Primary Prevention
| References | RR (95% CI) | References | RR (95% CI)
Total mortality
All studies Statin drugs Good quality | ^4^–^6,^ ^9^ ^4^–^6,^ ^9^ ^4^–^6,^ ^9^ | 1.11 (0.66 1.87) 1.11 (0.66 1.87) 1.11 (0.66 1.87) | ^3,^ ^7,^ ^8,^ ^16,^ ^17,^ ^19^ ^7,^ ^8,^ ^16,^ ^17,^ ^19^ ^7,^ ^8,^ ^16,^ ^17^ | 0.95 (0.62, 1.46) 0.87 (0.37, 2.00)* 0.45 (0.03, 7.00)*
CHD mortality
All studies Statin drugs Good quality | ^1,^ ^2,^ ^4^–^6,^ ^9^–^12^ ^4^–^6,^ ^9^–^12^ ^4^–^6,^ ^9^–^12^ | 0.74 (0.57, 0.96) 0.78 (0.60, 1.01) 0.78 (0.60, 1.01) | ^4^–^6,^ ^9^ ^4^–^6,^ ^9^ ^4^–^6,^ ^9^ | 1.07 (0.47, 2.40) 1.02 (0.11, 9.76) 1.02 (0.11, 9.76)
Nonfatal MI
All studies Statin drugs Good quality | ^1,^ ^2,^ ^4^–^6,^ ^9^–^12^ ^4^–^6,^ ^9^–^12^ ^4^–^6,^ ^9^–^12^ | 0.64 (0.50, 0.82) 0.63 (0.48, 0.83) 0.63 (0.48, 0.83) | ^7,^ ^8,^ ^16,^ ^17^ ^7,^ ^8,^ ^16,^ ^17^ ^7,^ ^8,^ ^16,^ ^17^ | 0.61 (0.22, 1.68) 0.61 (0.22, 1.68) 0.61 (0.22, 1.68)
CHD events ^†^
All studies Statin drugs Good quality | ^4^–^6,^ ^10^–^15,^ ^18^ ^4^–^6,^ ^10^–^15,^ ^18^ ^4^–^6,^ ^10^–^15,^ ^18^ | 0.79 (0.72, 0.88) 0.79 (0.72, 0.88) 0.79 (0.72, 0.88) | ^16,^ ^17,^ ^19^ ^16,^ ^17,^ ^19^ ^16,^ ^17^ | 0.87 (0.50, 1.49) 0.87 (0.50, 1.49) 0.54 (0.22, 1.30)
Revascularization
All studies Statin drugs Good quality | ^4^–^6,^ ^10^–^12^ ^4^–^6,^ ^10^–^12^ ^4^–^6,^ ^10^–^12^ | 0.70 (0.42, 1.16)* 0.70 (0.42, 1.16)* 0.70 (0.42, 1.16)* | ^16,^ ^17^ ^16,^ ^17^ ^16,^ ^17^ | 0.87 (0.33,2.31)^‡^ 0.87 (0.33,2.31)^‡^ 0.87 (0.33,2.31)^‡^

* P-value for heterogeneity <0.10

† CHD events in CARE, LIPID and ALLHAT defined as CHD mortality or nonfatal MI; in 4S as CHD mortality, non fatal MI or Resuscitated cardiac arrest; in AFCAPS as CHD mortality, nonfatal MI, unstable angina or sudden cardiac death, and in HPS as CHD mortality, nonfatal MI, stroke, or revascularization. See preceding Tables for full names of studies.

‡ Only one trial provided data on this outcome

Note: Statin drugs included lovastatin, pravastatin or simvastatin

Abbreviations

CHD, coronary heart disease; CI, confidence interval; MI, myocardial infarction; RR, relative risk.

## References for Appendix 3

1 Research Committee of the Scottish Society of Physicians. Ischemic Heart Disease: a secondary prevention trial using clofibrate. BMJ. 1971;4:775-784. [pmid: 4943606].
2 Group of Physicians of the Newcastle Upon Tyne Region. Trial of clofibrate in the treatment of ischemic heart disease. BMJ. 1971;4:767-775. [pmid: 4943605].
3 Dorr AE, Gundersen K, Schneider JC Jr, et al. Colestipol hydrochloride in hypercholesterolemic patients—effect on serum cholesterol and mortality. J Chronic Dis. 1978;31(1):5-14. [pmid: 346598].
4 Randomised trial of cholesterol lowering in 4444 patients with coronary heart disease: the Scandinavian Simvastatin Survival Study (4S). Lancet. 1994;344(8934):1383–1389.
5 Miettinen TA, Pyorala K, Olsson AG, et al. Cholesterol-lowering therapy in women and elderly patients with myocardial infarction or angina pectoris: findings from the Scandinavian Simvastatin Survival Study (4S). Circulation. 1997;96(12):4211-4218. [pmid: 9416884].
6 Pedersen TR, Berg K, Cook TJ, et al. Safety and tolerability of cholesterol lowering with simvastatin during 5 years in the Scandinavian Simvastatin Survival Study. Arch Intern Med. 1996;156(18):2085-2092. [pmid: 8862101].
7 The ACAPS Group. Rationale and design for the Asymptomatic Carotid Artery Plaque Study (ACAPS). Control Clin Trials. 1992;13(4):293-314. [pmid: 1330434].
8 Furberg CD, Adams HP Jr, Applegate WB, et al. Effect of lovastatin on early carotid atherosclerosis and cardiovascular events. Asymptomatic Carotid Artery Progression Study (ACAPS) Research Group. Circulation. 1994;90(4):1679-1687. [pmid: 7734010].
9 Byington RP, Furberg CD, Crouse JR 3rd, et al. Pravastatin, Lipids, and Atherosclerosis in the Carotid Arteries (PLAC-II). Am J Cardiol. 1995;76(9):54C-59C.
10 Sacks FM, Pfeffer MA, Moye LA, et al. The effect of pravastatin on coronary events after myocardial infarction in patients with average cholesterol levels. Cholesterol and Recurrent Events Trial investigators. N Engl J Med. 1996;335(14):1001-1009. [pmid: 8801446].
11 Lewis SJ, Sacks FM, Mitchell JS, et al. Effect of pravastatin on cardiovascular events in women after myocardial infarction: the cholesterol and recurrent events (CARE) trial. J Am Coll Cardiol. 1998;32(1):140-146. [pmid: 9669262].
12 Plehn JF, Davis BR, Sacks FM, et al. Reduction of stroke incidence after myocardial infarction with pravastatin: the Cholesterol and Recurrent Events (CARE) study. The Care Investigators. Circulation. 1999;99(2):216-223. [pmid: 9892586].
13 Prevention of cardiovascular events and death with pravastatin in patients with coronary heart disease and a broad range of initial cholesterol levels. The Long-Term Intervention with Pravastatin in Ischaemic Disease (LIPID) Study Group. N Engl J Med. 1998;339(19):1349–1357.
14 Tonkin AM, Colquhoun D, Emberson J, et al. Effects of pravastatin in 3260 patients with unstable angina: results from the LIPID study. Lancet. 2000;356(9245):1871-1875. [pmid: 11130382].
15 White HD, Simes RJ, Anderson NE, et al. Pravastatin therapy and the risk of stroke. N Engl J Med. 2000;343(5):317-326. [pmid: 10922421].
16 Downs JR, Clearfield M, Weis S, et al. Primary prevention of acute coronary events with lovastatin in men and women with average cholesterol levels: results of AFCAPS/TexCAPS. Air Force/Texas Coronary Atherosclerosis Prevention Study. JAMA. 1998;279(20):1615-1622. [pmid: 9613910].
17 Clearfield M, Downs JR, Weis S, et al. Air Force/Texas Coronary Atherosclerosis Prevention Study (AFCAPS/TexCAPS): efficacy and tolerability of long-term treatment with lovastatin in women. J Womens Health Gend Based Med. 2001;10(10):971-981. [pmid: 11788107].
18 Heart Protection Study Collaborative Group. MRC/BHF Heart Protection Study of cholesterol lowering with simvastatin in 20,536 high-risk individuals: a randomised placebo-controlled trial. Lancet. 2002;360(9326):7-22. [pmid: 12114036].
19 Allhat Officers Collaborative Research Group. The Antihypertensive, Lipid-Lowering Treatment to Prevent Heart Attack Trial. Major outcomes in moderately hypercholesterolemic, hypertensive patients randomized to pravastatin vs usual care: the Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT-LLT). JAMA. 2002;288(23):2998-3007. [pmid: 12479764].