# Appendix 1. Search Strategy

1 exp lovastatin/ or “lovastatin”.mp.
2 simvastatin.mp.
3 Pravastatin/ or “pravastatin”.mp
4 (atorvastatin or fluvastatin or rosuvastatin).mp.
5 statins.mp. or exp Hydroxymethylglutaryl-CoA Reductase Inhibitors/
6 1 or 2 or 3 or 4 or 5
7 Drug Evaluation/ or drug evaluation studies.mp.
8 comparative study/
9 7 or 8
10 6 and 9
11 limit 10 to human
12 limit 11 to english language
13 11 not 12
14 limit 13 to abstracts
15 12 or 14
16 6
17 limit 16 to (human and english language and (clinical trial or clinical trial, phase i or clinical trial, phase ii or clinical trial, phase iii or clinical trial, phase iv or controlled clinical trial or meta analysis or multicenter study or randomized controlled trial))
18 exp clinical trials/ or clinical trial$.tw.
19 exp cohort studies/
20 (cohort stud$ or longitudinal stud$ or prospective stud$).tw. (33965)
21 18 or 19 or 20
22 6 and 21
23 limit 22 to (human and english language)
24 17 or 23
25 15 or 24