# References

1 U.S. Preventive Services Task Force. Recommendations and Rationale: Screening for Lipid Disorders in Adults. Available at: http://www.ahrq.gov/clinic/uspstf/uspschol.htm.). Accessed: May 12, 2005.
2 National Cholesterol Education Project. Third Report of the Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel III): National Institutes of Health; September, 2002. NIH 02-5215.
3 Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults. Executive Summary of the Third Report of the National Cholesterol Education Program (NCEP) Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel III). JAMA. 2001;285:2486–2497.
4 Grundy SM, Cleeman JI, Bairey Merz CN, et al. Implications of Recent Clinical Trials for the National Cholesterol Education Program Adult Treatment Panel III Guidelines. Circulation. 2004;110:227-239. [pmid: 15249516].
5 Wilson PW, D'Agostino RB, Levy D, et al. Prediction of coronary heart disease using risk factor categories. Circulation. 1998;97:1837-1847. [pmid: 9603539].
6 Pignone MP, Phillips CJ, Lannon CM, et al. Screening for Lipid Disorders. Rockville, MD: Agency for Healthcare Research & Quality; April 2001. AHRQ Publication No. 01-S004.
7 Grady D, Chaput L, Kristof M. Systematic Review of Lipid Lowering Treatment to Reduce Risk of Coronary Heart Disease in Women. Rockville, MD: Agency for Healthcare Research and Quality; 2003.
8 Wilt T, Bloomfield H, MacDonald R, et al. Effectiveness of statin therapy in adults with coronary heart disease. Arch Intern Med. 2004;164(13):1427-1436. [pmid: 15249352].
9 Law MR, Wald NJ, Rudnicka AR. Quantifying effect of statins on low density lipoprotein cholesterol, ischaemic heart disease, and stroke: systematic review and meta-analysis. BMJ. 2003;326(7404):28.
10 Helfand M, Carson S, Kelley C. Drug Class Review on HMG-CoA Reductase Inhibitors (Statins), 2005; Available at: www.ohsu.edu/drugeffectiveness. Accessed: May 2005.
11 Conroy RM, Pyorala K, Fitzgerald AP, et al. Estimation of ten-year risk of fatal cardiovascular disease in Europe: the SCORE project. Eur Heart J. 2003;24(11):987-1003. [pmid: 12788299].
12 Assmann G, Schulte H, Funke H, et al. The emergence of triglycerides as a significant independent risk factor in coronary artery disease. Eur Heart J. 1998;19(Suppl M):M8-14. [pmid: 9821011].
13 Assmann G, Cullen P, Schulte H. Simple scoring scheme for calculating the risk of acute coronary events based on the 10-year follow-up of the Prospective Cardiovascular Münster (PROCAM) Study. Circulation. 2002;105:310-315. [pmid: 11804985].
14 Asia Pacific Cohort Studies Collaboration. Serum Triglycerides as a Risk Factor for Cardiovascular Diseases in the Asia-Pacific Region. Circulation. 2004;110(17):2678-2686. [pmid: 15492305].
15 Ferrario M, Chiodini P, Chambless LE, et al. Prediction of coronary events in a low incidence population. Assessing accuracy of the CUORE Cohort Study prediction equation. Int J Epidemiol. 2005;34(2):413-421. [pmid: 15659467].
16 Shai I, Rimm EB, Hankinson SE, et al. Multivariate assessment of lipid parameters as predictors of coronary heart disease among postmenopausal women: potential implications for clinical guidelines. Circulation. 2004;110(18):2824-2830. [pmid: 15492318].
17 McNeill AM, Rosamond WD, Girman CJ, et al. The metabolic syndrome and 11-year risk of incident cardiovascular disease in the Atherosclerosis Risk in Communities Study. Diabetes Care. 2005;28(2):385-390. [pmid: 15677797].
18 Ford I, Murray H, Packard CJ, et al. Long-term follow-up of the West of Scotland Coronary Prevention Study. N Engl J Med. 2007;357(15):1477-1486. [pmid: 17928595].
19 The Lipid Research Clinics Coronary Primary Prevention Trial results II: the relationship of reduction in incidence of coronary heart disease to cholesterol lowering. JAMA. 1984;251(3):365–374.
20 Frick M, Elo O, Haapa K, et al. Helsinki Heart Study: primary-prevention trial with gemfibrozil in middle-aged men with dyslipidemia. Safety of treatment, changes in risk factors, and incidence of coronary heart disease. N Engl J Med. 1987;317:1237-1245. [pmid: 3313041].
21 Shepherd J, Cobbe SM, Ford I, et al. Prevention of coronary heart disease with pravastatin in men with hypercholesterolemia. West of Scotland Coronary Prevention Study Group. N Engl J Med. 1995;333(20):1301-1307. [pmid: 7566020].
22 Downs J, Clearfield M, Weis S, et al. Primary prevention of acute coronary events with lovastatin in men and women with average cholesterol levels results of AFCAPS/TexCAPS. Air Force/Texas Coronary Atherosclerosis Prevention Study. JAMA. 1998;279:1615-1622. [pmid: 9613910].
23 MRC/BHF Heart Protection Study of cholesterol-lowering therapy and of antioxidant vitamin supplementation in a wide range of patients at increased risk of coronary heart disease death: early safety and efficacy experience. Eur Heart J. 1999;20(10):725–741.
24 Heart Protection Study Collaborative Group. MRC/BHF Heart Protection Study of cholesterol lowering with simvastatin in 20,536 high-risk individuals: a randomised placebo-controlled trial. Lancet. 2002;360(9326):7-22. [pmid: 12114036].
25 Colhoun HM, Betteridge DJ, Durrington PN, et al. Primary prevention of cardiovascular disease with atorvastatin in type 2 diabetes in the Collaborative Atorvastatin Diabetes Study (CARDS): multicentre randomised placebo-controlled trial. Lancet. 2004;364(9435):685-696. [pmid: 15325833].
26 ALLHAT Investigators. Major outcomes in moderately hypercholesterolemic, hypertensive patients randomized to pravastatin vs. usual care. JAMA. 2002;288:2998-3007. [pmid: 12479764].
27 Shepherd J, Blauw GJ, Murphy MB, et al. Pravastatin in elderly individuals at risk of vascular disease (PROSPER): a randomised controlled trial. Lancet. 2002;360(9346):1623-1630. [pmid: 12457784].
28 Amarenco P, Bogousslavsky J, Callahan A 3rd, et al. High-dose atorvastatin after stroke or transient ischemic attack. N Engl J Med. 2006;355(6):549-559. [pmid: 16899775].
29 Heart Protection Study Collaborative Group. MRC/BHF Heart Protection Study of cholesterol-lowering with simvastatin in 5963 people with diabetes: a randomised placebo-controlled trial. Lancet. 2003;361(9374):2005-2016. [pmid: 12814710].
30 Sever PS, Dahlof B, Poulter NR, et al. Anglo-Scandinavian Cardiac Outcomes Trial: a brief history, rationale and outline protocol. J Hum Hypertens. 2001;15(Suppl 1):S11-12. [pmid: 11685901].
31 ACAPS Group. Rationale and design for the Asymptomatic Carotid Artery Plaque Study (ACAPS). Control Clin Trials. 1992;13(4):293-314. [pmid: 1330434].
32 Furberg CD, Adams HPJ, Applegate WB, et al. Asymptomatic Carotid Artery Progression Study (ACAPS) Research Group. Effect of lovastatin on early carotid atherosclerosis and cardiovascular events. Circulation. 1994;90(4):1679-1687. [pmid: 7734010].
33 Clearfield M, Downs JR, Weis S, et al. Air Force/Texas Coronary Atherosclerosis Prevention Study (AFCAPS/TexCAPS): efficacy and tolerability of long-term treatment with lovastatin in women. J Womens Health Gend Based Med. 2001;10(10):971-981. [pmid: 11788107].
34 Walsh JME, Pignone M. Drug Treatment of Hyperlipidemia in Women. JAMA. 2004;291(18):2243-2252. [pmid: 15138247].
35 Thompson PD, Clarkson P, Karas RH. Statin-associated myopathy. JAMA. 2003;289(13):1681-1690. [pmid: 12672737].
36 de Lemos JA, Blazing MA, Wiviott SD, et al. Early intensive vs. a delayed conservative simvastatin strategy in patients with acute coronary syndromes: phase Z of the A to Z trial. JAMA. 2004;292(11):1307-1316. [pmid: 15337732].
37 Department of Health and Human Services, Food and Drug Administration. Steven K. Galson, MD, MPH letter to Sidney M. Wolfe, MD. Available at: http://www.fda.gov/cder/drug/infopage/rosuvastatin/crestor_CP.pdf.). Accessed: May 2005.
38 La Rosa J, He J, Vupputuri S. Effects of statins on risk of coronary heart disease. A meta-analysis of randomised controlled trials. JAMA. 1999;282(24):2340-2346. [pmid: 10612322].
39 Tolman K. The liver and lovastatin. Am J Cardiol. 2002;89:1374-1380. [pmid: 12062731].
40 LaRosa J, Grundy S, Waters D, et al. Intensive lipid lowering with atorvastatin in patients with stable coronary disease. N Engl J Med. 2005;352(14):1425-1435. [pmid: 15755765].
41 Haney EM, Huffman LH, Bougatsos C, et al. Screening for lipid disorders in children and adolescents: systematic evidence review for the U.S. Preventive Services Task Force. Evidence Synthesis Number 47. Rockville, Maryland: Agency for Healthcare Research and Quality, July 2007. Available at: http://www.ahrq.gov/clinic/uspstf/uspschlip.htm. Assessed: 2008.
42 Sever PS, Dahlof B, Poulter NR, et al. Rationale, design, methods and baseline demography of participants of the Anglo-Scandinavian Cardiac Outcomes Trial. ASCOT investigators. J Hypertens. 2001;19(6):1139-1147. [pmid: 11403364].
43 Sever PS, Dahlof B, Poulter NR, et al. Prevention of coronary and stroke events with atorvastatin in hypertensive patients who have average or lower-than-average cholesterol concentrations, in the Anglo-Scandinavian Cardiac Outcomes Trial—Lipid Lowering Arm (ASCOT-LLA): a multicentre randomised controlled trial. Lancet. 2003;361(9364):1149-1158. [pmid: 12686036].