# Results

## Key Question 1. How frequent is elevated total cholesterol in men younger than age 35 and women younger than age 40, and what proportion have an overall 10-year risk of cardiac events of 10% or greater?

ATP III recommends screening all men and women aged 20 and above, and points out that young adults who are in the upper quartile of cholesterol levels are at high long-term risk of cardiac mortality. The USPSTF in 2001 recommended selective screening of younger men and women who smoke, have a history of hypertension, or have diabetes mellitus. They argued that, in young adults without specific cardiovascular risk factors, the absolute reduction in risk as a result of treating dyslipidemia is small. They recommended that all patients, regardless of lipid levels, should be offered counseling about the benefits of eating a diet low in saturated fat and high in fruits and vegetables, engaging in regular physical activity, avoiding tobacco use, and maintaining a healthy weight.

A minority of men younger than 35 and women younger than 45 are candidates for lipid-lowering therapy. Based on National Health and Nutrition Examination Survey (NHANES) III data (http://www.cdc.gov/nchs/about/major/nhanes/nh3data.htm) in the general US population, 8.9% of men aged 18–35 and 12.3% of women aged 18–45 have a TC>240 mg/dL. Among men aged 18–35 and women younger than 40 who do not smoke, do not have a history of hypertension, and do not have diabetes mellitus, no combination of ATP-III risk factors (TC up to 310 mg/dL, HDL-c, and systolic blood pressure) would result in a predicted 10-year risk of major cardiovascular events greater than 10%. Some men younger than 35 years of age who smoke, and those who have diabetes, have a 10-year risk that exceeds 10%, but these men can be identified for lipid testing based on their history. In NHANES, among all nondiabetic women aged 40–45 years, the probability of being at intermediate risk or high risk were 1.45% and 0%, respectively; all of these women had a history of hypertension or smoking.

No new evidence examines whether targeting young adults in the upper quartile of risk is more effective than recommending a healthy diet, physical activity, avoidance of tobacco products, and maintenance of a healthy weight to all.

## Key Question 2. What evidence supports the use of triglyceride levels as part of an initial screening panel?

Both the USPSTF and ATP III recommend screening with a panel that includes a TC and HDL-C, and both recommend using the average of two readings to estimate the TC and HDL-C more accurately. ATP III recommends that the initial screening lipid panel should also include a triglyceride level, while the USPSTF recommends obtaining a second lipid panel that includes a triglyceride level if the initial screening results indicate that the patient is at high risk.

The 2001 USPSTF systematic evidence review found: 1) mixed, inconclusive evidence that triglycerides are independently associated with an increased risk of CHD, and 2) insufficient evidence to conclude that treating persons with isolated increased triglycerides would reduce future CHD events.

Triglyceride level was not a consistent independent predictor of incident CHD events in prospective studies conducted in middle-aged, relatively low and moderate-risk populations. The Framingham Study^5^ and European Systematic Coronary Risk Evaluation (SCORE)^11^ risk scoring systems do not include a measure of serum triglycerides, but a risk score derived from the Prospective Cardiovascular Munster (PROCAM) cohort does.^12,^ ^13^ The PROCAM risk score was derived from 10-year follow-up of 5,389 German men 35 to 65 years of age. In this relatively low-risk population, triglyceride levels were an independent predictor of coronary events after adjustment for age, low-density lipoprotein cholesterol (LDL-C), HDL-C, systolic blood pressure, smoking history, family history of heart attack in a first-degree relative before age 60 years, and diabetes. In an original data meta-analysis of 26 Asian Pacific cohorts (n=96,224), triglyceride levels were associated with coronary events and with stroke after adjustment for age, sex, systolic blood pressure, smoking status, and total-to-HDL cholesterol ratio.^14^ However, most of the cohorts included in the Asia Pacific analysis did not have sufficient data to adjust for the other risk factors that contribute to the Framingham risk score.

Other cohort studies did not find triglycerides to be an independent predictor of coronary events or of stroke. In the CUORE study, a pooled analysis of 11 Italian cohorts (n=6,865), triglyceride levels were not an independent predictor of coronary events.^15^ The best proportional hazards equation included age, total cholesterol, systolic blood pressure, cigarette smoking, HDL cholesterol, diabetes mellitus, hypertension drug treatment, and family history of CHD. The coefficients of the CUORE model agreed with those of the Framingham Heart Study. However, the CUORE coefficients for triglyceride levels and for HDL-C differed from those of the PROCAM model. Forcing triglyceride level into the CUORE model reduced the influence of HDL-C and age but did not improve overall prediction. This finding was similar to that of an analysis from the Nurses Health Study that found that a fasting triglyceride level did not provide additional prediction of coronary events after adjustment for other lipid parameters, particularly HDL-C.^16^ In an 11-year cohort study of 12,089 black and white middle-aged individuals followed in the Atherosclerosis Risk in Communities (ARIC) population, triglyceride level was not correlated with cardiovascular events (coronary events or stroke) after adjustment for Framingham risk factors and components of the metabolic syndrome. Except for the triglyceride level, every component of the metabolic syndrome (elevated blood pressure, low HDL-C, elevated fasting glucose, and large waist circumference) was associated with a higher risk of coronary events.^17^

These results suggest that, although the triglyceride level is a strong univariate predictor of CHD events, its association with such events is reduced substantially by adjustment for other risk factors. ATP III argues that, if this is true, triglyceride level may be a marker for atherogenic remnant lipoproteins, other lipid risk factors (small LDL particles and low HDL), nonlipid risk factors (elevated blood pressure), and emerging risk factors (insulin resistance, glucose intolerance, prothrombotic state). That is, even if it is not an independent risk factor, if it is a marker for these non-traditional risk factors, a triglyceride level may identify individuals at high cardiovascular risk who might otherwise be missed. Specifically, elevated triglycerides (and the metabolic syndrome) might identify individuals at high long-term risk of developing cardiovascular disease who have not yet developed enough atherosclerotic disease to have a high short-term risk of events.

Would these patients benefit from treatment for elevated triglyceride levels? Older evidence on this question is inconclusive,^6^ as are recent clinical trials. Because statins, like some other classes of lipid-lowering drugs, reduce triglyceride levels as well as LDL-C levels, they cannot help determine how much of the benefit is due to lowering triglycerides. In the future, clinical trials of drugs that selectively reduce triglyceride levels may determine whether targeted therapy for hypertriglyceridemia can reduce the short-term risk of cardiovascular events in people who have already developed lesions. However, such trials do not address whether screening for high triglycerides can prevent the development of cardiovascular disease in the long-term. We identified no trials with clinical endpoints that enrolled patients with elevated triglyceride levels who would not otherwise qualify for treatment.

ATP-III also argues that initial testing should include a triglyceride level to improve the accuracy of the TC and HDL tests. Specifically, with adjustment for the triglyceride level, elevated LDL will be more frequently detected, and the HDL determination will be slightly more accurate. We did not seek new evidence on these points, which were addressed in detail in the 2001 USPSTF review.

## Key Question 3. What are the optimal screening intervals in the general population and in patients at high risk for CHD events?

We did not identify new evidence relevant to the appropriate interval to screen for hyperlipidemia in the general population, or in subgroups of the general population.

## Key Question 4. What risk factors should be used to select patients for drug therapy?

### Treatment Decisions in Relation to Overall Risk and LDL-C Levels

Treatment decisions depend not only on the LDL-C level but also on the number and nature of other cardiac risk factors. ATP II defined three risk groups based on their history and risk status. The three risk groups had different LDL-C goals and different intensities of LDL-lowering therapy. In 2001, the USPSTF endorsed the ATP II guidelines, which identified high LDL cholesterol as a potential target for LDL-lowering drug therapy for persons with multiple risk factors whose LDL levels are high (≥160 mg/dL) after dietary therapy, and for persons with 0–1 risk factors whose LDL levels are ≥190 mg/dL after dietary therapy.

As described in Table 1, in ATP-III the decision to treat depends on the presence of CHD or CHD equivalents, the LDL-C level, and the 10-year risk of events. The CHD group now includes persons who have a history of coronary disease as well as other persons who have an absolute 10-year risk for developing major coronary events (myocardial infarction and coronary death) >20%. ATP III also expanded the concept of a “CHD risk equivalent,” which refers to persons without established CHD who should be treated in the same manner as those who have established CHD. The CHD risk equivalents are diabetes, clinical manifestations of noncoronary forms of atherosclerotic disease (peripheral arterial disease, abdominal aortic aneurysm, and carotid artery disease; that is, transient ischemic attacks or stroke of carotid origin or 50% obstruction of a carotid artery); or 2 or more risk factors with a 10-year risk for hard CHD events > 20%. Compared with ATP-II, in ATP III many of these risk categories are assigned a lower threshold for initiating drug therapy and a lower target LDL-C level.

Table 2 describes trials of statins, conducted in outpatient or community settings, which included at least some subjects who had no history of coronary artery disease. Except for AFCAPS and WOSCOPS, all of these trials were published since the 2001 USPSTF guidelines were released. Longer-term follow-up results from WOSCOPS, published in October 2007, confirm the persistence of a beneficial decrease in coronary events over ten years after the end of the trial in men with elevated cholesterol but without a previous myocardial infarction.^18^ The reader is referred to the 2004 ATP III update^4^ for a more detailed description of major recent trials.

Table 2 Statin Trials that Included a Primary Prevention Group

Trial Quality | Drug/Dose | Risk Status | Baseline LDL (mg/dL) | Study length (years) | % LDL reduction | Relative risk for coronary events (95% CI)
AFCAPS^22^ Good | Lovastatin 20mg–40mg | Average risk, no history of CAD | 150 | 5.2 | 25% | 0.63 (0.50–0.79)
ALLHAT-LLT^26^ Fair-Good | Pravastatin 40mg | Hypertensive moderately high LDL-C and at least one additional CHD risk factor | 145 | 4.8 | 24% | 0.91 (0.79–1.04)
ASCOT-LLA^30,^ ^42,^ ^43^ Fair-Good | Atorvastatin 10mg | HTN plus CHD risk factors | 133 | 3.3 | 35% | 0.71 (0.59–0.86)
CARDS^25^ Good | Atorvastatin 10 mg | Type 2 diabetes, no history of CVD | 117 | 3.9 | 36% | 0.63 (0.48–0.83)
HPS^24^ Good | Simvastatin 40mg | History of CVD, diabetes, or non-coronary vascular disease | 131 | 5.5 | 30% | 0.73 (0.67–0.79)
PROSPER^27^ Good | Pravastatin 40mg | 70–82 years old, history of CHD or risk factors | 147 | 3.2 | 27% | 0.85 (0.74–0.97)
SPARCL^28^ Good | Atorvastatin 80 mg | Stroke or TIA within 1–6 months, no history of CHD | 133 | 4.9 | 53% | 0.80 (0.69–0.92)
WOSCOPS^21^ Good | Pravastatin 40mg | High risk, no history of CAD | 192 | 4.9 | 16% | 0.69 (0.57–0.85)

As of 1999, randomized trials of the benefits of lipid-lowering therapy in people without established CHD enrolled primarily middle-aged men of European descent.^19^–^22^ Many of the trials in Table 2 enrolled subjects who were under-represented in earlier trials. For example, the Heart Protection Study (HPS) targeted individuals in whom the risk and benefits of cholesterol lowering were uncertain (women, those over 70 years, diabetics, those with non-coronary vascular disease, and those with average or below-average cholesterol).^23,^ ^24^ In ASCOT-LLA (Anglo-Scandinavian Cardiac Outcomes Trial—Lipid-lowering Arm), about 24.5% of the subjects were diabetics. CARDS (Collaborative Atorvastatin Diabetes Study) was conducted in patients with type 2 diabetes without elevated cholesterol levels (LDL <107 mg/dL).^25^ Patients had no history of cardiovascular disease but at least one of the following risk factors: retinopathy, albuminuria, current smoking, or hypertension.

In ALLHAT-LLT (Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack—Lipid-lowering Arm),^26^ nearly half the subjects were women, 35% were diabetic, 15% had a history of CHD, and about 35% were black. Pravastatin did not reduce all-cause mortality or cardiovascular event rates. The reason for the lack of benefit of pravastatin in ALLHAT-LLT is unclear, but the high rate of use of statins in the control group is frequently cited as a possible explanation.

The good-quality Prospective Study of Pravastatin in the Elderly at Risk (PROSPER) trial was designed to examine the benefits of statin therapy in women and in the elderly.^27^ Overall, pravastatin reduced the composite primary endpoint (CHD death, nonfatal MI, fatal/nonfatal stroke) from 16.2% in the placebo group to 14.1%. There was also a reduction in transient ischemic attacks, but not in strokes, in the pravastatin group. There was no effect on all-cause mortality, which was 10.5% in the placebo group vs. 10.3% in the pravastatin group. The reduction in coronary heart disease deaths in the pravastatin group (absolute risk reduction 24%; 95% CI 1% to 42%) was balanced by an increase in cancer deaths (absolute risk increase 28%; 95% CI 3% to 68%).

In the recent SPARCL trial,^28^ 4,731 patients who had had a stroke or transient ischemic attack in the past one to six months were randomized to high-dose atorvastatin (80 mg) or placebo. After a median 4.9 years of follow-up, there was a 2.2% absolute reduction in the primary endpoint of fatal or nonfatal stroke (Adjusted hazard ratio 0.84; 95% CI 0.71 to 0.99). There was also a reduction in risk of major cardiovascular events, but an increase in the incidence of hemorrhagic stroke (Adjusted hazard ratio 1.66; 95% CI 1.08 to 2.55).

The results of these recent trials support the idea that patients who have “CHD risk equivalents” benefit from lipid-lowering therapy similar to that used in individuals who have known CHD.

### Treatment Decisions in Women

It is clear that lipid-lowering therapy, particularly statins, significantly reduced the risk of coronary events among women who have a history of coronary disease or diabetes.^8,^ ^25,^ ^29,^ ^30^ However, data for asymptomatic women who have no known coronary disease are not conclusive.

Although only one of the first 4 primary prevention trials (AFCAPS) enrolled postmenopausal women, the USPSTF in 2001 decided that the benefits could be extrapolated to women whose risk of CHD events was similar to that of the trial participants. The USPSTF recommended screening for women beginning at age 45 years, when the average risk of CHD events is similar for that of men at 35 years of age. For the elderly, younger adults, and other groups not well represented in the trials, the USPSTF recommended treatment for patients whose risk of CHD events was 0.6% to 1.5% per year, the range observed in the first four primary prevention trials of drug therapy for hyperlipidemia available in 1999. Because recent trials enrolled only high-risk enrollees, they do not provide evidence that the low end of this range should be changed.

A 2003 systematic review conducted by the University of California San Francisco-Stanford University Evidence-based Practice Center found that 15,917 women had been included in randomized controlled-trials (RCTs) of various lipid-lowering treatments.^7^ Four of these trials^22,^ ^31^–^33^ enrolled women (n=7,673) without prior CHD (primary prevention). The characteristics of these trials, their results, and the results of a meta-analysis are shown in Appendix 3. In the meta-analysis for the primary prevention studies (Appendix 3, Results table, right panel), “...there was insufficient evidence of reduced risk of any clinical outcome in women.” In the secondary prevention studies, women had statistically significant reductions in CHD mortality, CHD events, nonfatal MI, and revascularization; their magnitude was similar to those for men. The risk for total mortality was not lower in women treated with lipid lowering, regardless of whether they had prior CHD or not. In a more recent meta-analysis of primary prevention trials, the pooled relative risk reduction for women was 0.87 (95% CI: 0.69 to 1.09).^34^ Another trial, PROSPER, included a mixture of primary and secondary prevention populations. PROSPER revealed that pravastatin was more effective in men than in women.^27^ There were 3,000 women in the study. The baseline risk in men (n=2,804) was higher; in the placebo group, almost 20% of men and 13% of women had an event (CHD death, nonfatal MI, or stroke) over the 3 years of the study. For men, there was a statistically significant reduction in the primary endpoint (Hazard ratio 0.77, CI 0.65–0.92). For women, there was no apparent effect (Hazard ratio 0.96, CI 0.79–1.18).

### Treatment Decisions in Older Patients

Although evidence from primary prevention studies is lacking, recent secondary prevention trials deliberately recruited subjects 65 years and older to determine whether they benefit from lipid-lowering therapy. In the HPS, for example, simvastatin reduced major vascular events (28.7% vs. 23.6%) in subjects 70 years and older, and, in subjects aged 75 to 80 years at study entry, the benefit was even greater (32.3% vs. 23.1%; P<.001).^24^

In one meta-analysis of the 6 secondary prevention trials that have reported results for subjects 65 years and older, statins reduced all-cause mortality by 15%.^8^

### Treatment Decisions in Other Demographic Subgroups

Since 2001, few additional data are available from randomized trials on the effectiveness of lipid-lowering therapy in blacks and other racial and ethnic groups. In ALLHAT,^26^ 38% of the subjects were black, but ALLHAT was a negative trial in which there was no difference between the treatment and control groups for any subgroup.

## Key Question 5. What is the current evidence about the harms of drug therapy for lipid disorders?

The large randomized trials summarized above provide strong evidence about the balance of benefits and harms from drug therapy, particularly statins. Because they were analyzed on an intention-to-treat basis, the benefits in subjects who tolerated and complied with medication are diluted by the lack of benefit in subjects who discontinued medication because of side effects or did not complete the study for other reasons. Moreover, the mortality results of the trials indicate clearly that, for the enrolled subjects, and for the duration of the trials, statins are beneficial. The balance of benefits and harms of statin drugs over a longer time than the trials have observed remains unclear.

As strong as they are, these results do not ensure that the trial results are generalizable to individuals who would not meet the eligibility criteria for the trial. Some experts have voiced an additional concern, that broader use of statins and more aggressive therapy to meet lower LDL-C targets could lead to higher rates of serious harms than have been observed in trials.

Statins have rare but serious harms, especially in groups with identifiable risk factors for such events. Statin use is associated with a range of abnormalities, from mildly elevated serum creatine phosphokinase (CPK) levels, to myalgia, temporary or persistent muscle weakness, and rhabdomyolysis. Mild elevations in CPK are not well-studied because controlled trials usually record only markedly elevated levels as adverse events.

Myopathy is the best-studied harm. In placebo-controlled and direct comparison trials, rates of muscle complaints range from 1% to 4%.^10,^ ^35^ In the major clinical trials, rhabdomyolysis is uncommon. A 2003 review summarized published literature as well as data from the Food and Drug Administration (FDA) adverse event reporting system.^35^ In 28 trials combined there were 49 cases of myositis and 7 cases of rhabdomyolysis among 42,323 patients randomized to a statin, versus 44 cases of myositis and 5 of rhabdomyolysis among 41,535 patients randomized to placebo or to usual care.^35^ In the A to Z trial,^36^ which enrolled post-MI patients, there was a high incidence of myopathy (9 cases, 3 with rhabdomyolysis) in patients treated with simvastatin 80 mg/d. There were no cases of myopathy with the 20 mg or 40 mg doses. The incidence of fatal rhabdomyolysis is estimated from FDA reports at 0.15 per 1,000,000 prescriptions.

Data from pre-marketing trials suggest that higher doses of statins are associated with higher rates of myopathy. These data are summarized in an FDA letter released in March 2005 (available at: http://www.fda.gov/cder/drug/infopage/rosuvastatin/crestor_CP.pdf. See Figure 1 and the following discussion).^37^ This FDA document also estimates the frequency of voluntarily reported cases of rhabdomyolysis in the 6 months interval post-approval, ranging from 0 to 0.3 per 100,000 prescriptions (page 13).

Concomitant use of certain medications, including, for some statins, those that interact with the CYP3A4 pathway, increase the risk of rhabdomyolysis, as do other systemic lipid-lowering agents such as niacin and fibrates.

In controlled trials, among patients who have no history of liver disease, up to 2% of patients have elevation of liver enzymes (transaminases, primarily Alanine aminotransferase) > 3 times the upper limit of normal. Two meta-analyses of clinical trials^9,^ ^38^ as well as the HPS^24^ found rates of elevated transaminases to be no higher among patients taking statins than among those receiving placebo. A review focusing on lovastatin found that rates of Alanine aminotransferase levels 3 times the upper limit of normal were dose-dependent; the rate was 2.6% at 20 mg/day and 5% at 80 mg/day.^39^ The rate of hepatitis was 9.7 per million patient-treatment years, and the rate of liver failure (1 per 1.14 million patient-treatment years) was equivalent to the background rate of idiopathic acute liver failure. Similarly, in a trial of two doses of atorvastatin, the incidence of persistent elevations in liver aminotransferase levels was 2 per 1000 in patients taking atorvastatin 10 mg daily, versus 1.2 per 1000 in patients taking 80 mg daily.^40^