# Methods

## Data Sources

The 2001 systematic evidence review prepared for the USPSTF^6^ was based on searches of MEDLINE (1994 to December 1999) and the Cochrane Controlled Trials Registry through December 1, 1999. For this update, we searched the Cochrane Library (2004, Issue 4), MEDLINE (1966–February Week 1 2005), EMBASE (1980–February 4, 2005), PREMEDLINE (through February 9, 2005), and dossiers submitted by manufacturers of statins (Appendix 1). To identify key articles about the epidemiology, natural history, and detection of lipid levels and lipid disorders, we relied on the reference lists of the 2002 ATP III Final Report^2^ and the 2004 update to ATP III^4^, as well as recent systematic reviews,^7^–^9^ supplemented by a title and abstract search of MEDLINE and PREMEDLINE. All searches were restricted to articles published in English.

## Study Selection

We reviewed randomized trials of at least a 1-year duration that examined drug therapy with statins among patients without previously known CHD, and measured clinical end points including total mortality, CHD mortality, and nonfatal MI. To be included, the trial had to address primary prevention in the general population or in a subset of the general population identified on the basis of risk factors for CHD. We also included observational studies of the epidemiology of lipid disorders, screening to detect lipid disorders, risk factors for CHD, and the harms of statin therapy.

## Data Extraction and Quality Assessment

Our methods for abstracting information about the design, results, and internal validity of each included trial are described elsewhere.^10^ We used text and internal validity ratings from a previous review of statins^10^ to summarize the results of recent statin trials and of the safety of statins. We used standard USPSTF methods to rate the internal validity of trials and epidemiologic studies included in this update but not in the statins review (See Appendix 2).

## Data Synthesis and Analysis

We summarized new evidence relevant to discrepancies between USPSTF and ATP III recommendations in the context of earlier evidence from the 2001 evidence review conducted for the USPSTF, the final report of ATP III, and the 2004 ATP III update

## Funding

This study was funded by AHRQ under Contract Number 290-02-0024, Task Order Number 2, for the USPSTF, and by the Drug Effectiveness Review Project.