# Introduction

In 2001, the US Preventive Services Task Force (USPSTF)^1^ recommended that all men aged 35 and older, women aged 45 and older, men aged 20 to 35, and women aged 20 to 45 who are at increased risk for coronary heart disease (CHD) be screened for total cholesterol (TC) and high density lipoprotein cholesterol (HDL-C).^1^ In 2002, the National Cholesterol Education Program (NCEP) published new guidelines (Adult Treatment Panel III [ATP III]) for the diagnosis and management of lipid disorders.^2,^ ^3^ The NCEP guidelines were updated in August 2004 to include evidence from more recent trials.^4^

Both the USPSTF and ATP III embrace the principle that, in the short term, the benefits of screening and treatment depend on reducing the risk of major CHD events; that is, sudden coronary death or myocardial infarction (MI). They agree that treatment decisions should be based on the overall risk of having an event, not on lipid levels alone, and both recommend using Framingham^5^ projections to estimate risk.

The USPSTF and ATP III guidelines agree on many essential points, but there are also important differences between them (Table 1). The USPSTF recommendations^1^ address screening in asymptomatic adults who have no history of coronary heart disease. The scope of the NCEP guidelines^2,^ ^3^ is much broader. Management of patients with known heart disease, a major subject of the NCEP guidelines, is not relevant to the USPSTF. They also differ in their recommended target populations for screening, initial screening panel, frequency of screening, and criteria for initiating lipid-lowering therapy.

Table 1 Discrepancies in 2001 USPSTF and 2002/2004 ATP III Guidelines

Key Question | USPSTF | ATP-III | Eligible Evidence | Conclusions of Update
Target population
1) How frequent is elevated total cholesterol in men younger than age 35 and women younger than age 40, and what proportion have an overall 10-year risk of cardiac events of 10% or greater? | Men aged 35 and older. Women aged 40 and older. Men aged 20–34 and women aged 20–39 who have certain risk factors.* | Adults aged 20 and older. | Observational studies (cross-sectional, prospective cohort) | We did not identify new direct evidence addressing the target population for screening. (The Task Force has also examined a review of screening for lipid disorders in children and adolescents up to 21 years of age, published in July 2007,^41^ It is now examining a separate review of novel risk factors for CHD.)
Initial screening panel
2) What evidence supports the use of triglyceride levels as part of an initial screening panel? | TC and HDL-C, or TC alone if HDL-C unavailable. | TC, HDL-C, and triglyceride level, with calculated LDL-C. | Randomized controlled trials in patients with elevated triglyceride levels who would not otherwise qualify for treatment; Observational studies | Recent evidence is conflicting regarding the additional contribution of a serum triglyceride level to the identification of individuals at short-term risk for CHD events.
Frequency of screening
3) What are the optimal screening intervals in the general population and in patients at high risk for CHD events? | Once every 5 years. Shorter intervals for people who have lipid levels close to those warranting therapy. Longer intervals if several previous values have been reassuring. | Once every 5 years if 0–1 risk factors. Shorter intervals if; - 2 or more risk factors OR; - 0 to 1 risk factors and lipid levels close to those warranting therapy. | Observational studies | We did not identify new direct evidence from observational or experimental studies regarding follow-up testing or the frequency of screening.
Estimating Risk
4) What risk factors should be used to select patients for lipid-modifying drug therapy? | Not defined. | Four levels of risk are defined: CHD and CHD equivalents. Multiple risk factors (2+) and 10-year risk 10–20% Multiple risk factors (2+) and 10-year risk < 10% 0 to 1 risk factor and 10-year risk <10% | Observational studies | Evidence from epidemiologic studies as well as from good-quality randomized controlled trials support the idea that patients who have “CHD risk equivalents” benefit from lipid-lowering therapy similar to that used in individuals who have known CHD. For low-risk and some intermediate-risk individuals who have elevated LDL-C or decreased HDL-C, we did not identify new direct evidence relevant to the USPSTF advice to treat individuals younger than age 45 or older than age 65 if the annual incidence of coronary heart disease is at least 0.6% per year. There is new direct evidence demonstrating effective short-term primary prevention in high-risk individuals older than 65 and in high-risk individuals who have lower LDL-C levels than those enrolled in older trials. There is also strong evidence that lipid-lowering therapy is effective in women who have known coronary disease or diabetes. There is still insufficient direct evidence from primary prevention trials to determine the effectiveness of lipid-lowering therapy in other low-risk and some intermediate risk groups under-represented in older trials.
Harms of drug therapy
5) What is the current evidence about the harms of drug therapy for lipid disorders? | Not addressed in guideline. The literature review (through 1999) provided a detailed review of the adverse effects of statins and non-statin drug therapy. | Provides information about side effects and refers to 2002 NHLBI statement on safety of statins at www.nhlbi.nih.gov/guidelines/cholesterol/statins.htm | Randomized controlled trials and long-term observational studies | Statins have rare but serious harms, especially in groups with identifiable risk factors for such events. The balance of benefits and harms is clearly in favor of statin therapy among individuals enrolled in some, but not all, randomized trials of short-term primary prevention. However, the applicability of these findings to individuals at higher risk of adverse events is unclear. The long-term (>10 years) safety of statins is not known.

* Risk Factors: Diabetes; family history of cardiovascular disease before age 50 in male relatives or age 60 in female relatives; family history suggestive of familial hyperlipidemia; or multiple coronary heart disease risk factors (e.g., tobacco use, hypertension). These are not the same risk factors as those USPSTF uses for estimating the risk of cardiovascular events.

The purpose of this selective review was to guide the USPSTF in updating its 2001 recommendations. With input from the Agency for Healthcare Research and Quality (AHRQ), the USPSTF decided that it was critical to update only the parts of the Key Questions that pertain to discrepancies between the USPSTF recommendations and the most recent ATP III guidelines:

1) How frequent is elevated TC in men younger than age 35 and women younger than age 40, and what proportion have an overall 10-year risk of cardiac events of 10% or greater?
2) What evidence supports the use of triglyceride levels as part of an initial screening panel?
3) What are the optimal screening intervals in the general population and in patients at high risk for CHD events?
4) What risk factors should be used to select patients for lipid-modifying drug therapy?
5) What is the current evidence about the harms of drug therapy for lipid disorders?