# References

1 Nelson HD, Helfand M. Screening for chlamydial infection. Am J Prev Med. 2001;20(3 Suppl):95-107. [pmid: 11306238].
2 USPSTF. Screening for Chlamydial Infection: Recommendations and Rationale. Am J Prev Med. 2001;20(3S):90-4.
3 Centers for Disease Control and Prevention. Sexually Transmitted Disease Surveillance, 2004. Atlanta, GA: U.S. Department of Health and Human Services, September 2005.
4 Weinstock H, Berman S, Cates W Jr. Sexually transmitted diseases among American youth: incidence and prevalence estimates, 2000. Perspect Sex Reprod Health. 2004;36(1):6-10. [pmid: 14982671].
5 Hwang L, Shafer MA. Chlamydia trachomatis infection in adolescents. Adv Pediatr. 2004;51:379-407. [pmid: 15366781].
6 Silins I, et al. Chlamydia trachomatis infection and persistence of human papillomavirus. Int J Cancer. 2005;116(1):110-5. [pmid: 15756673].
7 Wallin KL, et al. A population-based prospective study of Chlamydia trachomatis infection and cervical carcinoma. Int J Cancer. 2002;101(4):371-4. [pmid: 12209962].
8 Miller WC, Zenilman JM. Epidemiology of chlamydial infection, gonorrhea, and trichomoniasis in the United States—2005. Infect Dis Clin North Am. 2005;19(2):281-96. [pmid: 15963872].
9 Risser WL, et al. The epidemiology of sexually transmitted infections in adolescents. Semin Pediatr Infect Dis. 2005;16(3):160-7. [pmid: 16044389].
10 Wiesenfeld HC, et al. Lower genital tract infection and endometritis: insight into subclinical pelvic inflammatory disease. Obstet Gynecol. 2002;100(3):456-63. [pmid: 12220764].
11 Miller WC, et al. Prevalence of chlamydial and gonococcal infections among young adults in the United States. Jama. 2004;291(18):2229-36. [pmid: 15138245].
12 Arya R, et al. Incidence of genital Chlamydia trachomatis infection in the male partners attending an infertility clinic. J Obstet Gynaecol. 2005;25(4):364-7. [pmid: 16091321].
13 Rottingen JA, Cameron DW, Garnett GP. A systematic review of the epidemiologic interactions between classic sexually transmitted diseases and HIV: how much really is known?. Sex Transm Dis. 2001;28(10):579-97. [pmid: 11689757].
14 Baeten JM, Overbaugh J. Measuring the infectiousness of persons with HIV-1: opportunities for preventing sexual HIV-1 transmission. Curr HIV Res. 2003;1(1):69-86. [pmid: 15043213].
15 Mardh PA. Influence of infection with Chlamydia trachomatis on pregnancy outcome, infant health and life-long sequelae in infected offspring. Best Pract Res Clin Obstet Gynaecol. 2002;16(6):847-64. [pmid: 12473286].
16 Datta SD , J.R., Papp J, McQuillan G, Weinstock H, Prevalence Of Chlamydia And Gonorrhea In The United States Among Persons Aged 14–39 Years, 1999-2002 abstract (TP-078), 16th Biennial meeting of the International Society for Sexually Transmitted Diseases Research (ISSTDR). Amsterdam, July 10–13, 2005). 2005.
17 Mertz KJ, et al. Findings from STD screening of adolescents and adults entering corrections facilities: implications for STD control strategies. Sex Transm Dis. 2002;29(12):834-9. [pmid: 12466728].
18 Centers for Disease Control and Prevention. Sexually Transmitted Disease Surveillance 2003 Supplement, Chlamydia Prevalence Monitoring Project. 2004.
19 Gaydos CA, et al. Sustained high prevalence of Chlamydia trachomatis infections in female army recruits. Sex Transm Dis. 2003;30(7):539-44. [pmid: 12838080].
20 Rietmeijer CA, et al. Incidence and repeat infection rates of Chlamydia trachomatis among male and female patients in an STD clinic: implications for screening and rescreening. Sex Transm Dis. 2002;29(2):65-72. [pmid: 11818890].
21 Johnson RE, et al. Screening tests to detect Chlamydia trachomatis and Neisseria gonorrhoeae infections—2002. MMWR Recomm Rep. 2002;51(RR-15):1-38. quiz CE1–4. [pmid: 12418541].
22 Cook RL, et al. Systematic review: noninvasive testing for Chlamydia trachomatis and Neisseria gonorrhoeae. Ann Intern Med. 2005;142(11):914-25. [pmid: 15941699].
23 Scholes D, et al. Prevention of pelvic inflammatory disease by screening for cervical chlamydial infection. N Engl J Med. 1996;334(21):1362-6. [pmid: 8614421].
24 Ostergaard L, et al. Home sampling versus conventional swab sampling for screening of Chlamydia trachomatis in women: a cluster-randomized 1-year follow-up study. Clin Infect Dis. 2000;31(4):951-7. [pmid: 11049776].
25 Clark KL, et al. Hospitalization rates in female US Army recruits associated with a screening program for Chlamydia trachomatis. Sex Transm Dis. 2002;29(1):1-5. [pmid: 11773871].
26 Duncan B, et al. Qualitative analysis of psychosocial impact of diagnosis of Chlamydia trachomatis: implications for screening. Bmj. 2001;322(7280):195-9. [pmid: 11159612].
27 Pimenta JM, et al. Opportunistic screening for genital chlamydial infection. II: prevalence among healthcare attenders, outcome, and evaluation of positive cases. Sex Transm Infect. 2003;79(1):22-7. [pmid: 12576608].
28 Darroch J, Myers L, Cassell J. Sex differences in the experience of testing positive for genital chlamydia infection: a qualitative study with implications for public health and for a national screening programme. Sex Transm Infect. 2003;79(5):372-3. [pmid: 14573831].
29 Shain RN, et al. Prevention of gonorrhea and Chlamydia through behavioral intervention: results of a two-year controlled randomized trial in minority women. Sex Transm Dis. 2004;31(7):401-8. [pmid: 15215694].
30 Burstein GR, et al. Predictors of repeat Chlamydia trachomatis infections diagnosed by DNA amplification testing among inner city females. Sex Transm Infect. 2001;77(1):26-32. [pmid: 11158688].
31 Fortenberry JD, B E, Katz BP, Orr DP. Post-treatment sexual and prevention behaviours of adolescents with sexually transmitted infections. Sex Transm Infect. 2002;78(5):365-8. [pmid: 12407242].
32 Whittington WLH, K C, Kissinger P, Oh MK, Fortenberry JD, Hillis SE, et al. Determinants of persistant and recurrent Chlamydial trachomatis infection in young women: results of a multicenter cohort study. Sex Transm Dis. 2001;28(2):117-23. [pmid: 11234786].
33 van de Laar MJ, Termorshuizen F, van den Hoek A. Partner referral by patients with gonorrhea and chlamydial infection. Case-finding observations. Sex Transm Dis. 1997;24(6):334-42. [pmid: 9243740].
34 Kamwendo F, et al. Gonorrhea, genital chlamydial infection, and nonspecific urethritis in male partners of women hospitalized and treated for acute pelvic inflammatory disease. Sex Transm Dis. 1993;20(3):143-6. [pmid: 8511708].
35 Khan A, et al. The prevalence of chlamydia, gonorrhea, and trichomonas in sexual partnerships: implications for partner notification and treatment. Sex Transm Dis. 2005;32(4):260-4. [pmid: 15788928].
36 Lim SW, Coupey SM. Are adolescent girls with Chlamydia infection notifying their partners?. J Pediatr Adolesc Gynecol. 2005;18(1):33-8. [pmid: 15749582].
37 van Duynhoven YT, et al. Patient referral outcome in gonorrhoea and chlamydial infections. Sex Transm Infect. 1998;74(5):323-330. [pmid: 10195026].
38 Mathews, C., et al., Strategies for partner notification for sexually transmitted diseases. The Cochrane Database of Systematic Reviews, 2001. Issue 4: p. Art. No.: CD002843. DOI: 10.1002/14651858.CD002843.
39 Schillinger JA, et al. Prevalence of Chlamydia trachomatis infection among men screened in 4 U.S. cities. Sex Transm Dis. 2005;32(2):74-7. [pmid: 15668611].
40 Golden MR. Expedited partner therapy for sexually transmitted diseases. Clin Infect Dis. 2005;41:630-633. [pmid: 16080085].
41 Golden MR, et al. Effect of expedited treatment of sex partners on recurrent or persistent gonorrhea or chlamydial infection. N Engl J Med. 2005;352:676-85. [pmid: 15716561].
42 Kissinger P, et al. Patient-delivered partner treatment for male urethritis: a randomized, controlled trial. Clin Infect Dis. 2005;41:623-9. [pmid: 16080084].
43 Hogben M, McCree DH, Golden MR. Patient-delivered partner therapy for sexually transmitted diseases as practiced by U.S. physicians. Sex Transm Dis. 2005;32(2):101-5. [pmid: 15668616].
44 Centers for Disease Control and Prevention, Sexually Transmitted Diseases Treatment Guidelines MMWR, 2002. 51: p. No. RR-6.
45 Magriples U, Copel JA. Can risk factor assessment replace universal screening for gonorrhea and Chlamydia in the third trimester?. Am J Perinatol. 2001;18(8):465-8. [pmid: 11733863].
46 Honey E, et al. Cost effectiveness of screening for Chlamydia trachomatis: a review of published studies. Sex Transm Infect. 2002;78(6):406-12. [pmid: 12473799].
47 Hu D, Hook EW 3rd, Goldie SJ. Screening for Chlamydia trachomatis in women 15 to 29 years of age: a cost-effectiveness analysis. Ann Intern Med. 2004;141(7):501-13. [pmid: 15466767].
48 Blake DR, Gaydos CA, Quinn TC. Cost-effectiveness analysis of screening adolescent males for Chlamydia on admission to detention. Sex Transm Dis. 2004;31(2):85-95. [pmid: 14743071].
49 Ginocchio RH, et al. The clinical and economic consequences of screening young men for genital chlamydial infection. Sex Transm Dis. 2003;30(2):99-106. [pmid: 12567164].
50 Steen R, et al. Evidence of declining STD prevalence in a South African mining community following a core-group intervention. Sex Transm Dis. 2000;27(1):1-8. [pmid: 10654860].
51 Steiner, K., et al., Screening in Jails is Associated with a Decrease in Community Prevalence of Chlamydia: San Francisco, 1997-2002[Abstract};. 15^th^ Biennial Congress, International Society for STD Research Conference, Ottawa, Canada, 27–30 July 2003. Abstract 0146
52 NCQA, The State of Health Care Quality, 2005; Industry Trends and Analysis, National Committee for Quality Assurance, Editor. 2005.
53 Stamm WE. Chlamydia Screening: Expanding the Scope. Ann Intern Med. 2004;141(7):570-2. [pmid: 15466776].