# Background

Chlamydia trachomatis is the most common sexually transmitted bacterial infection in the Untied States. In 2004, a total of 929,462 cases of chlamydial infection were reported to the Centers for Disease Control and Prevention (CDC) [3]. Because many cases are not reported, the actual number of new cases of chlamydial infection is thought to be more than 2.8 million per year [4].

## Symptoms and Sequelae of Chlamydial infection

In women, Chlamydia trachomatis commonly results in cervicitis and urethritis. Up to 40% of untreated cases of Chlamydia trachomatis in women progress to pelvic inflammatory disease (PID) [5]. Of those with PID, it has been estimated that 20% become infertile, 18% experience chronic pelvic pain, and 9% may have a tubal pregnancy [6]. Chlamydial infection may also increase the risk for cervical cancer [7]. After the acute phase of infection, many women appear to experience a long duration of low-grade infection [8]. Seventy-five to 85%, of genital chlamydial infections in women are asymptomatic [9]. Women with low-grade PID may not experience significant enough symptoms to seek medical attention; yet, these low-grade infections may progress to infertility and chronic pelvic pain [10].

In men, genital chlamydial infection is also likely to be asymptomatic. In one large national sample, only 5% of infected men reported symptoms [11]. Chlamydial infection in men can cause nongonococcal urethritis, acute epididymitis, and, in rare instances, may result in uretheral strictures and Reiter Syndrome [5, 12].

As with other inflammatory sexually transmitted infections (STIs), Chlamydial infection facilitates the transmission of HIV infection in both men and women in both the HIV carrier and recipient [13, 14].

Chlamydial infections are also related to adverse pregnancy outcomes, including miscarriages, premature rupture of membranes, pre-term labor, low birth weight, infant mortality, neonatal chlamydial infection, and postpartum endometritis [1, 5, 15].

## Epidemiology

Prevalence rates of chlamydial infection vary widely among populations. Age is the strongest predictor of risk. The CDC reports that 15- to 19-year-old women had the highest reported rates of chlamydial infection in 2004 (2,761.5 per 100,000 women, or 2.8%), followed by 20- to 24-year-old women (2,630.7 per 100,000 women, or 2.6%) [3]. Rates among older women, while steadily increasing in recent years, are lower: at 1,039.5 per 100,000 women aged 25–29 (1.0%) and 364.8 per 100,000 women aged 30–34 (0.36%) [3]. The highest rates among men were found in 20- to 24-year-olds (744.7 per 100,000 men, or 0.74%). [3]. The lower rates of infection in men reported to the CDC are largely due to decreased rates of testing. Datta and colleagues found a prevalence rate of 2.2% among 14- to 39-year-old women and men in a nationally representative study, with no statistically significant differences between the sexes [16]. This rate most likely underestimates the true prevalence of chlamydial infection in adults, as non-sexually active adults were included in the sample. Miller and colleagues used a nationally representative sample of 14,322 young adults aged 18–26 to estimate the prevalence of chlamydial infection [11]. In this young age group, they found prevalence rates of 4.7% in women and 3.7% in men.

Race is independently associated with chlamydial infection in the United States [1]. In 2004, the rate of chlamydial infection among African American women reported to the CDC was more than seven and a half times the rate among white women (1,722.3 and 226.6 per 100,000, respectively); the rate of chlamydial infection among African American males was 11 times that among white males (645.2 and 57.3 per 100,000, respectively) [3]. While a significant portion of this disparity is likely due to variations in reporting, other nationally representative studies have also found higher prevalence rates among African Americans and Hispanic Americans than white Americans [11].

While there is some geographic variation in the rates of chlamydial infection in the United States, chlamydial infection is more uniformly prevalent than gonorrhea and syphilis infection, [3].

The prevalence of chlamydial infection in some vulnerable populations is much higher than in the general population. Prevalence rates of 10% to 20% have been found in studies of incarcerated populations, army recruits, and patients at public STI clinics [17–20].

Other risk factors associated with chlamydial infection include having multiple sexual partners, having a new sexual partner or an infected sexual partner, inconsistently using barrier contraceptives, and having a history of previous or coexistent STIs [1].

## Screening for Chlamydial infection

In 2001, the USPSTF systematically reviewed the evidence regarding screening tests for chlamydial infection in non-pregnant women (33 studies), pregnant women (2 studies), and men (32 studies). They rated the overall body of evidence for all 3 populations as fair, noting that many studies were performed under study conditions rather than real-world conditions and that most studies did not utilize large screening populations with low prevalence rates. The review found that nucleic acid amplification tests (NAATs) had higher sensitivities and specificities than older antigen detection tests and higher sensitivities than culture. In 2001 the USPSTF did not provide clinical guidance as to which tests should be used, noting that the “choice of test will depend on issues of cost, convenience, and feasibility, which may vary in different settings.”

In 2002, the CDC published recommendations for screening tests to detect chlamydial infection. Their recommendations were based on a review that utilized many of the same studies considered by the USPSTF, with the addition of a large, multicenter study on screening technologies. The CDC found results similar to those of the USPSTF. On the basis of these data, the CDC recommended that NAATs be used for screening both women and men [21].

In 2005, Cook and colleagues published a systematic review of non-invasive testing for chlamydial infection [22]. The pooled sensitivity for 14 tests of Polymerase Chain Reaction (PCR) was 83.3% for urine and 85.5% for cervical swabs when testing women. The specificity was 99.5% for urine and 99.6% for cervical samples. The team found similar results when pooling fewer studies of 2 other types of NAATs (transcription-mediated amplification and strand displacement amplification). Pooled sensitivity for the 2 studies with prevalence rates of less than 5% was 85.8%, slightly higher than that for the overall pool of studies. The team found, for 12 studies of PCR in men, a pooled sensitivity of 84.0% for urine and 87.5% for uretheral samples. The specificity was 99.3% for urine and 99.2% for uretheral samples. There were no studies evaluating PCR testing in men with infection prevalence rates of less than 5% [22].