# Introduction

In 2001, the United States Preventive Services Task Force (USPSTF) commissioned a systematic review of the evidence on screening for chlamydial infection [1]. Based on this review, the USPSTF found good evidence supporting screening for chlamydial infection among asymptomatic women at increased risk for infection, including women at risk due to young age. It found less evidence regarding screening for chlamydial infection in pregnant women and, based on estimates of benefits and harms, recommended screening for pregnant women at increased risk. At that time, the USPSTF found a major gap in the evidence on the effectiveness of screening men for chlamydial infection for the purposes of reducing the incidence of infection and improving health outcomes among women. (For more information about the USPSTF and its methodologies, please visit: www.preventiveservices.ahrq.gov)

Specifically, in 2001 the USPSTF stated the following [2]:

1) The U.S. Preventive Services Task Force (USPSTF) strongly recommends that clinicians routinely screen all sexually active women aged 25 years and younger, and other asymptomatic women at increased risk for infection, for chlamydial infection. (A Recommendation)
2) The USPSTF makes no recommendation for or against routinely screening asymptomatic low-risk women in the general population for chlamydial infection. (C Recommendation)
3) The USPSTF recommends that clinicians routinely screen all asymptomatic pregnant women aged 25 years and younger and others at increased risk for infection for chlamydial infection. (B Recommendation)
4) The USPSTF makes no recommendation for or against routine screening of asymptomatic, low-risk pregnant women aged 26 years and older for chlamydial infection. (C Recommendation)
5) The USPSTF concludes that the evidence is insufficient to recommend for or against routinely screening asymptomatic men for chlamydial infection. (I Recommendation)

In 2005, the USPSTF determined that a brief, focused evidence review was needed to update its 2001 recommendation on screening for chlamydial infection. Staff of the Agency for Healthcare Research and Quality (AHRQ) reviewed the literature published on this topic between July 2000 and July 2005 and prepared this evidence update. The review focused on a search for direct evidence on the effect of screening asymptomatic individuals on health outcomes. The USPSTF reviewed this evidence to update its recommendations.