# Appendixes

Appendix 1. Abbreviations

Appendix 2. Units of Measure Conversion Formulas

Appendix 3. Search Strategies for Child and Adolescent Dyslipidemia

Appendix 4. Inclusion/Exclusion Criteria and Results of Searches

Appendix 5. U.S. Preventive Services Task Force Quality Rating Criteria

Appendix 6. Statistical Methods Used for Meta Analysis