# Appendix 6. Statistical Methods Used for Meta Analysis

Steps to get mean percentage change:

1 Use reported mean change.
2 If not reported, calculated using mean lipid level changes from endpoint to baseline of the treatment and control group.

Steps to get standard error (SE) for mean percentage change:

1 Use reported SE.
2 If SE is not reported and standard deviation (SD) is reported, calculated from SD.
3 If both SE and SD not reported, calculated from 95% CI if reported.
4 If none of above is reported, calculated from the reported mean lipid level change and the associated variance (or SD). Let [image] and [image] denote the mean lipid level change from endpoint to baseline of the control and treatment group, respectively, the variance of mean percentage change is given by
  using delta method.
  Let z = y - x/ x, where x and y denote the individual lipid level change from endpoint to baseline, then mean percentage change is given by the mean z, [image]. It could be shown that [image] could be approximated by Var ([image]) using delta-method.
5 If SD for endpoint is not available, use estimates of SD from baseline (or maximum estimates for HDL) to get a conservative estimate of SE for mean percent change.