# Appendix 4. Inclusion/Exclusion Criteria and Results of Searches

Key Questions | Applicable Searches | Abstract Level Inclusion / Exclusion Criteria | Paper Level Inclusion / Exclusion Criteria | Number of Abstracts Screened with Eligibility Criteria*^†^ | Number of Articles Reviewed from Abstracts and other Sources*^†‡^ | Number of Articles Included in Evidence Synthesis*^†^
Screening
2 | screening family history sensitivity | [underlined: Include:] | [underlined: Include:] | 780 | 369 | 160
| | RCTs, observational studies, cross-sectional studies, practice guidelines, meta analyses, or other reviews; | RCTs, observational studies, cross-sectional studies, practice guidelines, meta analyses, or other reviews;
| | Examines screening for dyslipidemia in children or adolescents, specifically risk factors, adverse effects of screening, tests or test performance; | Examines screening for dyslipidemia in children and adolescents, specifically family history, biological (obesity, insulin level, etc) and lifestyle (physical activity, diet, etc) risk factors, measurement of serum lipids (TC, HDL, LDL, TG), tests or test performance (sensitivity, specificity), other screening measurements, adverse effects of screening;
| | Information on background or cost | Information on background or cost;
| | [underlined: Exclude:] | For prevalence, normal values papers: include non-U.S.-based if n>100
| | Wrong publication type, or population; | For neonatal screening and testing papers: include only if has mutation analysis
| | Not relevant to topic, non-U.S./Western culture, or non-English language; | [underlined: Exclude:]
| | Examines metabolic syndrome, triglyceride specific outcomes, screening in secondary dyslipidemia | Wrong publication type, or population;
| | | Not relevant to topic, non-U.S./Western culture, or non-English language;
| | | Examines metabolic syndrome, triglyceride specific outcomes, screening in secondary dyslipidemia
Interventions
4–8, 10 | diet exercise drug outcomes | [underlined: Include:] | [underlined: Include:] | 1668 | 707 | 68
| | Treatment trials, longitudinal studies, natural history studies, cross sectional studies, practice guidelines, meta analyses, or other reviews; | RCTS, clinical controlled trials, non-controlled trials, observational studies, cross sectional studies, practice guidelines, meta analyses, or other reviews;
| | Examines interventions for dyslipidemia in children or adolescents, specifically drugs, diets, exercise or combinations, family history, risk factors, adverse effects of interventions, tests or test performance; | Examines interventions for dyslipidemia in children and adolescents, specifically drugs, diets, exercise, or combinations, lipid outcomes, other outcomes (intimal thickness, medial dilation, etc), adverse effects of interventions, tests and test performance; Information on background or cost;
| | Information on background or cost; | For natural history papers: include non-Western culture
| | For natural history papers: include non-Western culture | [underlined: Exclude:]
| | [underlined: Exclude:] | Wrong population type, or population (< 50% child/adolescent or no separate analysis for child/adolescent);
| | Wrong publication type or population; | Not relevant to topic, non-U.S./Western culture (except natural history papers), or non-English language;
| | Not relevant to topic, non-U.S./Western culture (except natural history papers), or non-English language; | Examines metabolic syndrome, triglyceride specific outcomes, screening in secondary dyslipidemia
| | Examines metabolic syndrome, triglyceride specific outcomes, screening in secondary dyslipidemia
Adverse Effects of Screening
3 | adverse effects | same as KQ 2 | same as KQ 2 | 163 | 84 | 8
Adverse Effects of Interventions
9 | adverse effects | same as KQ 1, 4–8, 10 | [underlined: Include:] | same as KQ 3 | same as KQ 3 | 81
| | | Treatment trials, longitudinal studies, natural history studies, meta analyses, or other reviews
| | | Examines adverse effects of dyslipidemia in children and adolescents, specifically from drugs, diets, exercise, or combinations;
| | | Information on background or cost
| | | [underlined: Exclude:]
| | | Wrong publication type, or population;
| | | Not relevant to topic, non-U.S./Western culture, or non-English language
Cost
11 | cost | [underlined: Include:] | same as cost abstract criteria | 26 | 15 | 7
| | Study of cost of screening and/or treatment for elevated cholesterol in children;
| | Information on background
| | [underlined: Exclude:]
| | Genetic screening or tracking study based on identified FH individual;
| | Wrong population;
| | Not relevant to topic, non-U.S./Western culture, or non-English language

* All abstracts were reviewed for applicability to other key questions.

† Duplicates may exist between key questions.

‡ Other sources include reference lists, experts, etc.