# Appendix 3. Search Strategies for Child and Adolescent Dyslipidemia

Adverse Effects

Database: Ovid MEDLINE(R) <1966 to September 2005>

Search Strategy:

1 exp Hyperlipidemia/
2 ((adverse$ adj effect$) or harm$ or stigma$ or prejudice$ or discriminate$). mp. or exp stress, psychological/et or exp life change events/ or exp prejudice/ or exp stereotyping/ or exp self concept/
3 exp “Wounds and Injuries”/et [Etiology]
4 exp hyperlipidemia/dt
5 exp Antilipemic Agents/ae, ct, to
6 1 and (2 or 3)
7 4 and 5
8 6 or 7
9 limit 8 to English language
10 8 not 9
11 limit 10 to abstracts
12 9 or 11
13 limit 12 to “all child (0 to 18 years)”

Cost

Database: Ovid MEDLINE(R) <1966 to September 2005>

Search Strategy:

1 exp HYPERLIPIDEMIA/
2 exp lipoproteins/bl
3 1 or 2
4 Mass Screening/
5 exp hyperlipidemia/di
6 3 and 4
7 5 or 6
8 exp “Costs and Cost Analysis”/
9 7 and 8
10 exp HYPERLIPIDEMIA/ec [Economics]
11 9 or 10
12 limit 11 to all children <0 to 18 years>
13 limit 12 to English language

Diet

Database: Ovid MEDLINE(R) <1966 to September 2005>

Search Strategy:

1 exp HYPERLIPIDEMIA/dh [Diet Therapy]
2 exp HYPERLIPIDEMIA/
3 exp Diet/
4 exp Diet Therapy/
5 3 or 4
6 2 and 5
7 1 or 6
8 limit 7 to human
9 limit 8 to all children <0 to 18 years>
10 limit 9 to English language
11 9 not 10
12 limit 11 to abstracts
13 10 or 12

Drug

Database: Ovid MEDLINE(R) <1966 to September 2005>

Search Strategy:

1 exp HYPERLIPIDEMIA/dt [Drug Therapy]
2 exp Antilipemic Agents/ad, ae, ct, tu, to [Administration & Dosage, Adverse Effects, Contraindications, Therapeutic Use, Toxicity]
3 exp HYPERLIPIDEMIA/
4 2 and 3
5 1 or 4
6 limit 5 to all children <0 to 18 years>
7 limit 6 to English language
8 6 not 7
9 limit 8 to abstracts
10 7 or 9

Exercise

Database: Ovid MEDLINE(R) <1966 to September 2005>

Search Strategy:

1 exp HYPERLIPIDEMIA/
2 exp lipoproteins/bl
3 1 or 2
4 exp Exercise Movement Techniques/
5 exercis$.mp.
6 (physical$ adj3 active$).mp. [mp=title, original title, abstract, name of substance, mesh subject heading]
7 (physical$ adj (fit or fitness)).mp. [mp=title, original title, abstract, name of substance, mesh subject heading]
8 4 or 5 or 6 or 7
9 3 and 8
10 limit 9 to all child <0 to 18 years>
11 limit 10 to English language
12 10 not 11
13 limit 12 to abstracts
14 11 or 13

Family History

Database: Ovid MEDLINE(R) <1966 to September 2005>

Search Strategy:

1 exp HYPERLIPIDEMIA/ge [Genetics]
2 exp HYPERLIPIDEMIA/
3 exp lipoproteins/bl
4 2 or 3
5 exp Disease Susceptibility/
6 4 and 5
7 1 or 6
8 exp RISK/
9 7 and 8
10 limit 9 to all child <0 to 18 years>
11 (family$ adj3 histor$).mp. [mp=title, original title, abstract, name of substance, mesh subject heading]
12 4 and 11
13 limit 12 to all child <0 to 18 years>
14 13 and 8
15 10 or 14
16 limit 15 to English language
17 15 not 16
18 limit 17 to abstracts
19 16 or 18

Outcomes

Database: Ovid MEDLINE(R) <1966 to September 2005>

Search Strategy:

1 exp Hyperlipidemia/co, dh, dt, th
2 exp Cerebrovascular Disorders/mo, pc, ep, et [Mortality, Prevention & Control, Epidemiology, Etiology]
3 exp Myocardial Ischemia/mo, pc, ep, et [Mortality, Prevention & Control, Epidemiology, Etiology]
4 1 and 2
5 1 and 3
6 4 or 5
7 exp “OUTCOME AND PROCESS ASSESSMENT (HEALTH CARE)”/
8 exp prognosis/
9 7 or 8
10 1 and 9
11 6 or 10
12 limit 11 to all child <0 to 18 years>
13 limit 12 to English language
14 12 not 13
15 limit 14 to abstracts
16 13 or 15

Screening

Database: Ovid MEDLINE(R) <1966 to September 2005>

Search Strategy:

1 exp HYPERLIPIDEMIA/
2 exp Lipoproteins/bl [Blood]
3 Cholesterol/bl [Blood]
4 Triglycerides/bl [Blood]
5 2 or 3 or 4
6 exp Mass Screening/
7 5 and 6
8 1 and 6
9 7 or 8
10 limit 9 to all child <0 to 18 years>
11 limit 10 to English language
12 10 not 11
13 limit 12 to abstracts
14 11 or 13

Sensitivity

Database: Ovid MEDLINE(R) <1966 to September 2005>

Search Strategy:

1 exp HYPERLIPIDEMIA/
2 exp Lipoproteins/bl [Blood]
3 Cholesterol/bl [Blood]
4 Triglycerides/bl [Blood]
5 2 or 3 or 4
6 1 or 5
7 exp “Sensitivity and Specificity”/
8 exp Diagnostic Errors/
9 7 or 8
10 6 and 9
11 limit 10 to all child <0 to 18 years>
12 limit 11 to English language
13 11 not 12
14 limit 13 to abstracts
15 12 or 14