# Appendix 2. Units of Measure Conversion Formulas

Conversion for TC (total cholesterol), HDL (high density lipoprotein) and LDL (low density lipoprotein)^*^ ^†^ :

* References:

www.ulb.ac.be/eraseme/edu/gastrocd/convers.htm

www.fatfreekitchen.com/cholesterol/cholesterol_units.html

www.unc.edu/~rowlett/units/scales/clinical_data.html

www.globalrph.com/conv_si.htm

www.nephron.com/cgi-bin/SI.cgi (conversion calculator)

These accessed December 15, 2004

^†^Note: for both TC and TG conversions, some people use rounded conversion factors to get from mg/dL to SI units (i.e. 0.0259 and 0.0113).

To get from SI units (mmol/L) to mg/dL multiply by 38.67.

To get from mg/dL to SI (in mmol/L) multiply by 0.02586.

Conversion for TG (triglycerides)^*^ ^†^ :

To get from SI units (mmol/L) to mg/dL multiply by 88.57.

To get from mg/dL to SI units, multiply by 0.01129.