# Appendix 1. Abbreviations

AAP: | American Academy of Pediatrics
AE: | Adverse Event
BL: | Baseline
BMI: | Body Mass Index [kg/m^2^]
CAD: | Coronary Artery Disease
CHD: | Coronary Heart Disease
CVD: | Cardiovascular Disease
DB: | Double Blind
EDRF/NO: | Endothelium-derived Relaxing Factor/Nitric Oxide
ET: | Treatment Group
FCH: | Familial Combined Hyperlipidemia
FCHL: | Familial Combined Hyperlipoproteinemia
FH: | Familial Hypercholesterolemia
FHTG: | Familial Triglyceridemia
FMD: | Flow Mediated Dilation
HC: | Hypercholesterolemia
HDL: | High Density Lipoprotein
HDL-C: | High Density Lipoprotein Cholesterol
HeFH: | Heterozygous Familial Hypercholesterolemia
HoF: | Homozygous Familial Hypercholesterolemia
HR: | Heart Rate
HTN: | Hypertension
IMT: | Intimal-medial Thickness
LDL: | Low-density Lipoprotein
LDL-C: | Low-density Lipoprotein Cholesterol
LRC: | Lipid Research Clinic
MI: | Myocardial Infarction
NA: | Not Applicable
NCEP: | National Cholesterol Education Program
NIH: | National Institute of Health
NR: | Not Reported
NS: | Not Significant
OCP: | Oral Contraceptive Pills
RCT: | Randomized Controlled Trial
RF: | Risk Factor
RR: | Risk Ratio
SEM: | Standard Error of Measure
SSF: | Sum of Skinfolds
TC: | Total Cholesterol
TG: | Triglycerides
VLDL: | Very Low-density Lipoprotein