# Evidence Tables

Evidence Table 1. Tracking of Serum Lipid Levels

Study, year arranged by cohort | N | Demographics | Duration of follow-up | Age at start | Age at follow-up | Fasting serum levels? | Correlation coefficients | | | | Other Outcome | Adjusted? If so, for what? | Comments
| | | | | | | TC | LDL | HDL | TG
Bogalusa Heart Study; Bogaulsa, LA
Bao, 1996 ^92^ | 1169 | 64% white, 36% black, 50% M; 50% F | 15 years but dates given are 15–17 years post start | 5–14 years | (calc) | Yes | 0.4–0.6 | 0.4–0.6 | 0.2–0.4 | 0.1–0.4 | | No
Freedman, 1985 ^17^ | 1052 | 49% M; 51% F 55% white, 45% black | 8 years | 2.5–14 years | | Yes | 0.54–0.63 | 0.55–0.71 | 0.25–0.43 | | | No, but values given are race and sex specific | Lipids appear to track better in black M vs. black F or whites
Berenson, 1979 ^93^ | 1052 | 212 for TC; 154 for LDL, HDL and TG | 2 years | 5 years | 7 years | Yes | 0.42 | 0.43 | 0.14 | 0.21 | | Yes for year 1, race, sex height at year 1, change in weight/height, change in ht. (MV regression) | Alphalipoprotein = HDL
| 1,052 | 281 for TC; 247 for TG; 245 HDL and LDL | 2 years | 8 years | 10 years | Yes | 0.58 | 0.69 | 0.23 | 0.31 | | No
| 1,052 | 323 for TC; 270 for LDL, HDL and TG | 2 years | 11 years | 13 years | Yes | 0.49 | 0.64 | 0.30 | 0.35 | | No
| 1,052 | 241 for TC; 200 for LDL, HDL and TG | 2 years | 14 years | 16 years | Yes | 0.52 | 0.58 | 0.41 | 0.22 | | No
Child and Adolescent Trial for Cardiovascular Health Cohort Study; Multi-centered in U.S.
Kelder, 2002 ^3^ | 3,659 at grade 8 (3rd follow-up point); HDL done on a random 30% of population | 51% M, 49% F; 71% White, 13% AA, 13% Hispanic, 3% other | 6 years | 3rd grade (mean age 8.8 years) | 8th grade (mean age 14.1 years) | No | 0.66 | NR | 0.62 | NR
| 4,019 | same | 2 years | 3rd grade (mean age 8.8 years) | 5th grade (mean age 11.1 years) | No | 0.73 | NR | 0.73 | NR
| 3,659 | same | 3 years | 5th grade (mean age 11.1 years) | 8th grade (mean age 14.1 years) | No | 0.7 | NR | 0.65 | NR | | No | % remaining in highest quintile for 3rd grade to 5th grade: 59% for TC; 63% for HDL. % remaining in lowest quintile for 3rd grade to 5th grade: 59% for TC; 60% for HDL. For 3rd to 8th grade: lowest 53% for TC, 52% for HDL; highest 55% for TC, 55% for HDL
Muscatine Study; Muscatine, IA
Clarke, 1978 ^94^ | 7,371 | 3,521 M; 3,850 F | 2 years | 5–16 years | | | 0.68 | | | 0.44 | | No
| 3,268 | 1,558 M; 1,710 F | 4 years | 6–14 years | | | 0.63 | | | 0.4 | | No | After 4 years, 40% of those in the highest quintile for TG remained in that quintile.
| 816 | 408 M; 408 F | 6 years | 8–12 years | | | 0.61 | | | NA | | No | After 6 years, 50% of those originally in the highest quintile for TC remained in that quintile.
Lauer, 1989 ^95^ | 2,446 | 1,167 M; 1,279 F | 12–14 years | 8–18 years | 20–30 years | Yes (LRC method) | | | | | | | Paper reports percent variability of adult lipids according to tobacco, alcohol and OCP use.
| 99 | 55 M; 54 F | same | 7–8 years | 20–25 years | | M: 0.56, F: 0.64 | M: 0.56, F: 0.65 | M: 0.07, F: -0.25 | NA | | No
| 612 | 292 M; 311 F | same | 9–10 years | 20–25 years | | M: 0.58, F: 0.49 | M: 0.56, F: 0.47 | M: 0.07, F: 0.01 | NA | | No
| 1,018 | 476 M; 542 F | same | 11–12 years | 20–25 years | | M: 0.51, F: 0.54 | M: 0.47, F: 0.53 | M: -0.04, F: 0.06 | NA | | No
| 339 | 490 M; 551 F | same | 13–14 years | 20–25 years | | M: 0.51, F: 0.52 | M: 0.47, F: 0.49 | M: -0.02, F: 0.11 | NA | | No
| 1,041 | 155 M; 184 F | same | 13–14 years | 26–30 years | | M: 0.52, F: 0.52 | M: 0.50, F: 0.49 | M: 0.16, F: 0.08 | NA | | No
| 767 | 352 M; 415 F | same | 15–16 years | 20–25 years | | M: 0.64, F: 0.53 | M: 0.60, F: 0.49 | M: -0.03, F: 0.15 | NA | | No
| 568 | 263 M; 305 F | same | 15–16 years | 26–30 years | | M: 0.63, F: 0.55 | M: 0.56, F: 0.50 | M: 0.06, F: 0.10 | NA | | No
| 615 | 299 M; 316 F | same | 17–18 years | 20–25 years | | M: 0.72, F: 0.54 | M: 0.63, F: 0.56 | M: -0.07, F: 0.13 | NA | | No
| 479 | 233 M; 246 F | same | 17–18 years | 26–30 years | | M: 0.64, F: 0.48 | M: 0.61, F: 0.45 | M: 0.06, F: 0.04 | NA | | No
Beaver County Lipid Study, Beaver County, PA
Stuhldreher, 1991 ^96^ | 295 | 48.7 M | 16 years | 11–14 years | 27–30 (mean age 28) | Yes for follow-up values; baseline values measure calorimetrically by the ferric chloride-sulfuric acid method | M: 0.38; F: 0.51 | NA | NA | NA | | No
Lipid Research Clinics Program, multi-centered, U.S.
Namboodiri, 1984 ^97^ | 103 | 56 M, 47 F | 0–30 months (median 3 months) | <20 years | <20 years | Yes, LRC | M: 0.762, F: 0.782 | NA | NA | M: 0.374, F: 0.510 | | Not reported, but paper states that “correlations were also computed with the advariate adjusted lipid values; the results were generally similar.”
| 105 | 55 M, 50 F | 7–52 months (median 29 months) | <20 years | <20 years | Yes, LRC | M: 0.703, F: 0.604 | M: 0.672, F: 0.592 | M: 0.488, F: 0.241 | M: 0.436, M: 0.331 | | As stated above
| 102 | 54 M, 48 F | 7–102 months (not explicitly stated) | <20 years | <20 years | Yes, LRC | M: 0.593, F: 0.604 | NA | NA | M: 0.363, F: 0.522 | | As stated above
Laskarzewski, 1979 ^98^ | 108 | 46% M; 54% F; 81% White, 18% Black, <1% Asian. | 7 years | 7–14 years | 14–21 years | Yes, LRC | 0.68 | 0.61 | 0.53 | 0.39
Fels Longitudinal Study; Cincinnati, OH
Guo, 1993 ^99^ | 96 | NR | 4 years | 9–21 years | 13–25 | Yes, LRC | 0.77 | 0.78 | 0.57
| 96 | NR | 6 years | 9–21 years | 15–27 | | 0.63 | 0.67 | 0.43
| 96 | NR | 8 years | 9–21 years | 17–29 | | 0.58 | 0.61 | 0.31
| 96 | NR | 10 years | 9–21 years | 19–31 | | 0.61 | 0.58 | 0.34
| 96 | NR | 12 years | 9–21 years | 21–33 | | 0.72 | 0.65 | 0.46
Baumgartner, 1991 ^100^ | 69 | 27 F; 42 M 100% White | unclear | 12–18 years | up to age 21 years | Yes, LRC | M: 0.63, F: 0.56 | M: 0.60, F: 0.52 | M: 0.43, F: 0.79 | M: 0.58, F: 0.53 | | | Used Foulkes-Davis tracking index (using Dallal program), TC, TG, LDL for boys and TC, HDL for girls were statistically significant.
Aerobics Center Longitudinal Study, Cooper Institute, Dallas Texas
Eisenmann, 2004 ^110^ | 48 | 12 F; 36 M | 11 yrs | 12–18 years (mean age 15.8) | mean age 26.6 | Yes | 0.62 | NR | 0.6 | 0.54 | TC:HDL ratio 0.78 | length of follow-up used as a covariate
| | Mean weigh 61.5kg
NON-U.S. COHORTS
Amsterdam Growth & Health Study
Twisk, 1997 ^101^ | 181 | | 14 years | 13–16 years | | Yes | tracking coefficient: 0.71 | NA | tracking coefficient: M: 0.51, F: 0.65 | NA
Kindergarten Study, Basel, Switzerland
Mohler, 1996 ^102^ | NR | NR | 5 years | 5 years | 10 years | No, capillary blood morning sample not fasting | 0.07 (NS) | 0.2 | 0.19
| NR | NR | 4 years | 10 years | 14 years | No | 0.2 | 0.29 | 0.21
| 249 | NR | 9 years | 5 years | 14 years | No | 0.09 (NS) | 0.19 | 0.16
Quebec, Canada
Vobecky, 1988 ^103^ | 88 at risk children | 41 M, 47 F | 9 years | 3–36 months | 9–11 years | Yes (LRC method) | OR for TC≥200 mg/dL: 4.35 (1.78–10.63) | OR for LDL>125 mg/dL: 3.88 (1.85–8.14) | OR for HDL<40mg/dL: 2.10 (0.89–4.97)
Quebec Family Study
Katzmarzyk, 2001 ^104^ | 147 | 76 M, 71 F | 12+1.5 years | 8–18 years | | Yes | NA | NA | M: 0.58, F: 0.56 | M: 0.37, F: 0.20 | TC/HDL ratio: M: 0.51, F: 0.57 | Yes, initial age and length of follow-up period
Helsinki, Finland
Kallio, 1993 ^105^ | 162 | NR | 5 years | birth | 5 years | Cord blood sample at birth, scalp vein sample at 2,4,6,9,12 mos, non-fasting | 0.01 | NA | NA | NA | | No
| 162 | NR | | 2 months | 5 years | | 0.31 | 0.43 | 0.26 | 0.26
| 162 | NR | | 4 months | 5 years | | 0.29 | NR | NR | NR
| 162 | NR | | 6 months | 5 years | | 0.32 | 0.2 | 0.21 | 0.27
| 162 | NR | | 9 months | 5 years | | 0.36 | 0.41 | 0.39 | 0.52
| 162 | NR | | 12 months | 5 years | | 0.47 | 0.58 | 0.29 | 0.37 | | No
Toledo Area Study; Toldeo, Spain
Bastida, 2002 ^106^ | 38 | 21 F, 17 M | 4 years | births | 4 years | 12 hour fast for 4 year olds, cord blood sample at birth | 0.35 | 0.53 | 0.49 | NR
Cardiovascular Risk in Young Finns Study; mulit-centered in Finland
Porkka, 1991 ^107^ | 2,236 | 47.6% M | 6 years | 3–18 years | | Yes | 0.63 | 0.66 | 0.58 | 0.36 | | No
Porkka, 1994 ^108^ | 883 | 414 M, 469 F | 12 years | 3–18 years | (15–30 years) | Yes | M: 0.58, F: 0.48 | M: 0.58, F: 0.53 | M: 0.58, F: 0.53 | M: 0.37, F: 0.33 | | No | M showed more tracking than F
| 187 | 97 M; 90 F | 12 years | 3 years | 15 years | Yes | M: 0.60, F: 0.51 | M: 0.62, F: 0.57 | M: 0.64, F: 0.51 | M: 0.25, F: 0.46 | | No
| 160 | 74 M; 86 F | 12 years | 6 years | 18 years | Yes | M: 0.56, F: 0.37 | M: 0.60, F: 0.47 | M: 0.56, F: 0.44 | M: 0.13, F: 0.32 | | No
| 156 | 77 M; 79 F | 12 years | 9 years | 21 years | Yes | M: 0.63, F: 0.52 | M: 0.58, F: 0.53 | M: 0.56, F: 0.60 | M: 0.18, F: 0.22 | | No
| 149 | 64 M; 85 F | 12 years | 12 years | 24 years | Yes | M: 0.57, F: 0.60 | M: 0.56, F: 0.59 | M: 0.69, F: 0.52 | M: 0.45, F: 0.21 | | No
| 115 | 51 M; 64 F | 12 years | 15 years | 27 years | Yes | M: 0.40, F: 0.40 | M: 0.44, F: 0.51 | M: 0.57, F: 0.48 | M: 0.53, F: 0.58 | | No
| 116 | 51 M; 65 F | 12 years | 18 years | 30 years | Yes | M: 0.73, F: 0.51 | M: 0.67, F: 0.48 | M: 0.54, F: 0.56 | M: 0.49, F: 0.37 | | No
Eno, East Finland
Fuentes, 2003 ^109^ | 82 | 49 M, 33 F | 8 years | 7 years | 15 years | Yes | Yes | NA | NA | NA | | Gender, body weight, parental education, family history of obesity, family history high cholesterol, family history CVD and BMI | TC decreased more steeply in boys than in girls from age 7 to 15, but no statistically significant age-gender interaction was found.

Abbreviations M = Male; F = Female

Evidence Table 2. Risk Factors

Study, year | Population and Setting | N | Aims | Measures Used | Adjusted Analysis | Results
| | | | | | Activity | Aerobic Capacity / Cardiovascular Fitness | Diet | Family History | Overweight or other Biological Composition Measures | Other Biological | Other Miscellaneous
Andersen, 2003 ^135^ | Randomly-selected Danish children ages 9 and 15 | 1020 | To determine whether the number of participants with multiple coronary heart disease (CHD) risk factors exceeded the number expected from a random distribution. To establish whether and to what extent clustering of risk factors occurs in Danish children and adolescents. | Cardiovascular fitness: Estimated from maximal power output in a cycle test with progressively increasing workload until exhaustion. | X | NE | Those who had a high level of cardiovascular risk factors (4 or 5 risk factors) had a physical fitness level 1.2 standard deviations lower than mean values for the population. | NE | NE | BMI: Those who had a high level of cardiovascular risk factors (4 or 5 risk factors) had a BMI 1.6 standard deviations higher than mean values for the population. Risk factors included TC, HDL, TG, serum insulin and blood pressure. | NE | NE
| | | | Anthropometric measures: SSK (biceps, triceps, subscapular and suprailiac) | | | Authors conclude study found clustering of risk factors for metabolic syndrome.
| | | | BMI
| | | | Venous blood samples: Following overnight fast
| | | | Risk factors defined as: TC, HDL, TG, serum insulin and blood pressure
Bergstrom, 1997 ^136^ | Healthy Swedish adolescents aged 14 to 17. | 879 | To assess the relationship between physical fitness and BMI and suggested cardiovascular risk indicators of lipids, insulin, ferritin and blood pressure; as well as physical activity and dietary intake. | Activity: Self-report 7-day records and questionnaire. Physical training and other physical exercise graded on a 6-graded scale. | X | Physical activity: + correlated HDL, boys only (0.008, 95%CI, 0.001,0.014) | Positive relationship between running time and TG | Fat intake: + correlate HDL boys only (0.013, 95%CI, 0.003,0.023) inverse correlate TG girls only (-0.013, 95%CI, -0.022,-0.003) | NE | BMI inversely related to HDL (boys -0.027, 95%CI, -0.044,-0.009; girls -0.019, 95%CI,-0.031,-0.007) | NE | NE
| | | | Cardiovascular fitness: 3 km running test | | | Boys: 0.014, 95%CI, 0.000,0.028 | Iron intake: Inverse correlate ferritin boys only (-37.995, 95%CI, -73.237,-2.752) | | BMI + related to LDL (boys 0.037, 95%CI, 0.003,0.071; girls 0.036, 95%CI 0.006,0.067)
| | | | Anthropometric: BMI, SSF (biceps, triceps, subscapular, suprailiac skinfolds) | | | Girls: 0.016, 95%CI, 0.005,0.027 | | | BMI + related to insulin (boys 0.383, 95%CI, 0.193,0.572; girls 0.305, 95%CI, 0.128,0.483)
| | | | Diet: Self-report 7-day record | | | | | | Degree of adiposity is the most important factor in explaining differences between lipid and insulin values between adolescents with different levels of fitness.
| | | | Blood: lipids, insulin, ferritin
| | | | Blood pressure
| | | | Chronic disease history
Bonora, 1992 ^137^ | 18 yr old males, Verona Italy | 1293 | To evaluate the relation of either total body fat or body fat localization in several risk factors for atherosclerosis (serum lipids, insulin, and blood pressure) | Body mass index (obese = BMI of >27) | X | NE | NE | NE | NE | Total body fat is independently associated with: HDL, HDL/TC, TG, insulin, systolic blood pressure, diastolic blood pressure (p<.001). Not significant for total cholesterol or LDL. Total body fat is a better predictor of risk than waist/hip ratio (body fat localization). | NE | NE
| | | | Waist and hip circumferences (body fat distribution)
| | | | Total body fat or fat free mass (electrical resistance)
| | | | Serum cholesterol (HDL, LDL, & Total)
| | | | Triglycerides
| | | | Insulin
| | | | Blood pressure
| | | | Smoking, alcohol use, physical activity
Bonora, 1996 ^138^ | Healthy Italian men in Verona, Italy aged 18 or 38. Subset of those in the Verona Young Men Artherosclerosis Risk Factors Study. Our focus is on the 18 year old population only. | 188 | To examine to what extent differences in total body fat content, regional fat distribution, and lifestyle contribute to differences in the cardiovascular risk profile of middle-age vs young men. | Activity: Questionnaire on physical activity at work and during leisure time, classification into light, moderate and intense | X | Not included in multiple linear regression analysis | Not included in multiple linear regression analysis | NE | NE | Only muliple linear regression analysis results reported here. | NE | NE
| | | | Anthropometric: BMI, waist circumference, hip circumference, estimate of fat-free mass and total body fat (body electrical resistance) | | | | | | BMI, waist/hip ratio, and insulin levels strongly intercorrelated.
| | | | Blood sample after overnight fast: TC, HDL, TG. LDL calculated. Hypertriglyceridemia: TG > 250 mg/dL. Hypercholesterolemia: TC >240 mg/dL. | | | | | | BMI predicted TG (30% of this risk factor variability). Std coefficient 0.48, t-value 3.1, p<0.005.
| | | | HDL: abnormal if < 35 mg/dL. Insulin measured by Hales and Randle method.
| | | | Smoking
| | | | Daily alcohol intake: Grams consumed per day
| | | | Blood pressure: Hypertension defined as systolic ≥ 160 mmHg and/or diastolic ≥ 95mmHg
Demerath, 2003 ^139^ | 5th grade children in 14-rural West Virginia counties | 1338 | To examine the feasibility and utility of conducting a school-based obesity and cardiovascular disease risk factor screening program in a rural Appalachian population. | Anthropometric measures: BMI | X | NE | NE | NE | NE | TC: Greater risk of high TC among obese vs non-overweight (OR 2.4, p< 0.05), sensitivity 50%, specificity 71% | NE | NE
| | | | Blood samples: Whole blood from finger prick, with portable Cholestech LDX analyzers to measure TC and HDL-C. | | | | | | HDL: Lower among obese vs non-overweight (OR 5.3, p<0.05), sensitivity 66%, specificity 73%
DeStefano, 1995 ^140^ | Schoolchildren in rural Wisconsin aged 5 to 15 | 2726 for multivariate analysis | To evaluate determinants, especially dietary, of serum lipid concentrations in schoolchildren in a community-wide screening. | Family history: Brief questionnaire completed by parents or children | X | NE | NE | TC and LDL: Associated with butter and egg consumption | TC and LDL: strong association with family history of hypercholesterolemia (r=0.184 and 0.174, respectively) | Increased BMI: Related to adverse levels of all lipids and lipoproteins (TC, LDL, HDL, TG). | NE | Parent who smokes: negative association with TC:HDL ratio
| | | | Anthropometric measures: BMI | | | | HDL: Associated with butter and lard, negative association with vegetable shortening, whole grain bread | TC:HDL ratio: associated with having 1st degree relative with hypercholesterolemia. | BMI: Associated with TC:HDL ratio
| | | | Diet: brief questionnaire completed by parents or children. Most diet questions open-ended with questions on consumption during past week or during average day. | | | | Triglycerides: Associated with magerine, nonfat milk; negative association with eggs.
| | | | Venous blood samples after 12 hour overnight fast: TC, HDL, calculated LDL | | | | TC:HDL ratio: no strong association with diet
Douglas, 1996 ^141^ | Youth aged 5 – 19, predominantly African American and Hispanic, who live in an inner city environment. | 506 | To determine whether adding the criterion of obesity to family history would increase the yield of screening | Family history: Data collected at appointment. | X | NE | NE | NE | Predictor of higher cholesterol vs no family history (p<0.001). | Obesity defined as BMI > 20% above ideal BMI. | NE | NE
| | | | Anthropometric: BMI | | | | | Odds ratio of those with family history of hypercholesterolemia having high cholesterol: 2.28 (95% CI=1.70 to 2.86). | Predictor of higher cholesterol: correlation to non-fasting TC: p<0.001.
| | | | Diet: Question from HANES-1 | | | | | Sensitivity of family history as screening tool: 24% | OR of obese screenees having hypercholesterolemia: 1.74 (95% CI=1.34 – 2.14).
| | | | Blood samples: Nonfasting cholesterol (TC, TG) via finger stick. Those with elevated TC were asked to return for a fasting lipid profile via venipuncture (TC, TG, HDL). | | | | | Use of family history of CVD, hypertension, myocardial infarction, stroke produced similar results. | Multiple linear regression analysis: obesity related to hypercholesterolemia when controlling for age and family history (p<0.001).
| | | | Elevated TC: 170 mg/dl | | | | | Specificity: 88% | Sensitivity in screening for hypercholesterolemia: 42%
| | | | Elevated TG: 100 mg/dl | | | | | Positive predictive value: 51% | Specificity: 71%
| | | | | | | | | Negative predictive value: 69% | Positive predictive value: 41%
| | | | | | | | | | Negative predictive value: 72%
| | | | | | | | | | Predictive value of family history and obesity combined: Sensitivity: 49%, Specificity: 64%, Positive predictive value: 41%, Negative predictive value: 71%
DuRant, 1982 ^142^ | Black children and adolescents aged 7 – 15 who were economically disadvantaged and participated in a 6-week organized community recreation program | 84 | To evaluate the influence of a family history of CHD and CHD risk factors on the TC/HDL and LDL/HDL ratios in a group of black children and adolescents | Family history: Family health questionnaire re: 1st and 2nd degree relatives administered to parent. | X | NE | NE | NE | Parental CHD risk factors with significant effects on LDL/HDL and TC/HDL: stroke, diabetes mellitus, obesity. Stroke and age, diabetes and age, and obesity and age interactions in TC/HDL, LDL/HDL. Children with family history of stroke: <LDL/HDL; this difference was less apparent in adolescents. For TC/HDL, from childhood to adolescence > increase for those with a family history for stroke. Non-stroke history: small < in TC/HDL from childhood to adolescence. No difference in LDL/HDL or TC/HDL between children with and without family history of diabetes. Both > in adolescents with family history of diabetes, < in those without this history. Males: LDL/HDL same in those with/without obese family member. Females: higher LDL/HDL in those with obese family member. From childhood to adolescence, those with an obese family member showed > LDL/HDL vs those without an obese family member. Obesity, age, sex interaction effect on TC/HDL, with males with obese family members <TC/HDL from childhood to adolescence. Females with an obese family member had the highest TC/HDL levels, which increased from childhood to adolescence. | NE | NE | NE
| | | | Anthropometric measures: Triceps skinfold thickness
| | | | Diet: 24-hour intake history
| | | | Venous blood samples: Drawn after 12-hour fast, TC, TG, HDL. LDL calculated.
DuRant, 1983 ^143^ | Middle class white males aged 11 –17 recruited from local boy scout troops. | 50 | To examine the relationship between reported physical activity levels and HDL, LDL /HDL ratio, and TC/LDL among white male adolescents. | Activity: Questionnaire of usual level of physical activity (hours watching tv, reading and studying, team sports during previous school year, sports/activities performed ≥ 3 days/week continuously for ≥ 1 hour at a time, days of jogging per week, days bike riding per week) Exercise capacity tested by mechanically braked bicycle ergometer. | X | Days jogged per week: 2nd strongest predictor of TC/HDL (r=0.29); strongest predictor of LDL/HDL (r=-0.32) | Maximum exercise capacity not related to lipid levels. | Not significant in multiple regression | NE | NE | Age: Strongest predictor of HDL (r=-0.42), and TC/HDL (r=0.38) | Television watched per night: 2nd strongest predictor of HDL- (r=-0.42), 3rd strongest predictor of TC/HDL
| | | | Anthropometric: Weight, height, relative body weight (Weight-for-height index) triceps skinfold, resting pulse, blood pressure | | | | | | | Height: 3rd strongest predictor of HDL (r=-0.31) | Hours spent reading per day: 2nd strongest predictor of LDL/HDL (r=0.27)
| | | | Diet: 48-hour diet history kept by parents, with dietary recall completed by a registered dietician. | | | | | | | Systolic blood pressure: predictor of TC/HDL (r=0.30); of LDL/HDL (r=0.23) | Smoking and alcohol use not significant in multiple regression.
| | | | Blood sample after 12 hour fast: TC, HDL, LDL
| | | | Other: Cigarettes smoked per day, alcohol consumed per week.
DuRant, 1993 ^144^ | 4 and 5 year old African American, Hispanic and Caucasian children in the Texas Studies of Child Activity and Nutrition (SCAN) program. | 123 | To examine relationships among indicators of physical activity, physical fitness, and body composition with serum lipid and lipoprotein levels in young children. | NA | X | TC: Not significant | TG: negative correlation with percentage of time in higher activity level, work load. | NE | NE | TG: positive correlation with sum of skinfolds at year 1 and 2, and with waist/hip ratio and heart rate at year 2. | NE | NE
| | | | | | LDL: Not significant | | | | TSC: at year 2, correlated with year 1 waist/hip ratio, but year 2 waist/hip ratio not significant
| | | | | | TG: Negative correlation with mean activity level | | | | LDL: correlated with year 1 waist/hip ratio
| | | | | | | | | | HDL: correlated with sum of skinfolds at year 2
| | | | | | | | | | LDL/HDL ratio: positive correlation with year 1 waist/hip and year 2 sum of skinfolds
| | | | | | | | | | TSC/HDL ratio: positive correlation with year 1 waist/hip and year 2 sum of skinfolds
Dwyer, 1994 ^145^ | Australian schoolchildren aged 7 – 15 | 1919 | To relate objective measures of fitness to standard CHD risk factors on a large representative sample of children, to assess overall associations and determine whether threshold effects are present. | Endurance fitness: physical work capacity on a Monark bicycle ergometer. | X | Not significant for TC or HDL. | Not significant for TC or HDL. | NE | NE | BMI | NE | NE
| | | | Measure for fitness analysis: ratio of work capacity to lean body mass. | | | | | | TC - Negative correlation (p<.01)
| | | | Anthropometric: BMI, skinfold thickness at 4 sites | | | | | | HDL - Negative correlation (p<.001)
| | | | Serum lipids: measured after 12 hour fast. Lipid Research Clinic procedures followed. Plasma total cholesterol, triglycerides and HDL determined. | | | | | | TG - correlated (p<.001)
| | | | | | | | | | Sum of skinfolds:
| | | | | | | | | | TG - correlated (p<.001)
| | | | | | | | | | HDL - correlated (p<.001)
Eisenmann, 2002 ^146^ | Runners between age 8 and 15 who consistently placed within the top 5 finishers of road races 10 km or more by age and gender. | 54 | To examine age- and sex-associated variation in subcutaneaous andipose tissue (SAT) and its association with blood lipoproteins among adolescent distance runners. | Activity: Self-reported running volumes | X | All subjects very active: self-reported mean training volumes 1503 (males) and 1865 (females) km per year. | NE | NE | NE | Increase in SUM6: associated with > in LDL-C, TG and TC:HDL in adolescent males (p<0.05) | NE | NE
| | | | Anthropometric: SUM6: subcutaneous measures of triceps, biceps, subscapular, supra-iliac, abdominal and medial calf. TER: (trunk-to-extremity ratio) ratio of 3 trunk skinfolds to sum of 3 extremity skinfolds. SAT: (subcutaneous adipose tissue) TER regressed on SUM6, residuals retained to represent an index of relative SAT independent of overall subcutaneous fatness | | | | | | In adolescent females: associated with < in HDL-C and > in TG (p<0.05).
| | | | Venous blood samples: following 12 hour fast and 24 hours after last bout of exercise. TC, TG, HDL-C, LDL-C. | | | | | | TER not significant
Freedman, 1999 ^18^ | 5 – 17 year old males and females examined in 7 cross-sectional studies conducted by the Bogalusa Heart Study between 1973 and 1994. | 9167 | To examine the relationship of cut points for overweight derived from several national studies (Quetelet index, >95th percentile) to adverse risk factor levels and risk factor clustering. | Anthropometric: Quetlet index/BMI (kg/m2). Triceps and subscapular skinfolds. Overweight: defined as Quetlet index above the smoothed 95th percentile of combined data from 5 national surveys conducted between 1963 and 1994. | X | NE | NE | NE | NE | Overweight: defined as Quetlet index above the smoothed 95th percentile of combined data from 5 national surveys conducted between 1963 and 1994. | NE | NE
| | | | Blood samples: TC, TG, LDL, HDL. High level of TC: >200 mg/dL, TG: ≥ 130 mg/dL, LDL: 130 mg/dL. HDL: <35 mg/dL considered low. | | | | | | TC: Overweight children 2.4× more likely to have elevated TC
| | | | | | | | | | LDL-C: 3.4 × more likely
| | | | | | | | | | TG: 7.1 × more likely
| | | | | | | | | | HDL-C: 3.4× more likely to be <35mg/dL
| | | | | | | | | | Use of overweight as screening tool could identify 50% of school children who had 2 or more risk factors.
| | | | | | | | | | Sensitivity for TC: 24%
| | | | | | | | | | TG: 47%
| | | | | | | | | | LDL: 28%
| | | | | | | | | | HDL: 25%
Fripp, 1985 ^147^ | Males aged 15 –17 recruited from the 10th grade in a regional public high school who tested as having low-moderate to moderate levels of physical fitness | 37 | To evaluate the interrelationship between aerobic capacity, ponderosity, and atherosclerotic risk factors by examining exercise duration, maximum oxygen consumption, body mass index, systolic and diastolic blood pressure, and levels of plasma lipids of male adolescents with low-to-moderate levels of physical fitness. | Family history questionnaire. Aerobic capacity: progressive treadmill test. Anthropometric: BMI, ponderal index. Venous blood samples after overnight fast: TC, TG, LDL-C, HDL-C, LDL-B. | X | NE | HDL-C higher with increased exercise duration (p<.05) | NE | NE | BMI: positive association with triglyceride level (p<.05); negative association with HDL-C (p<.05). | NE | NE
| | | | | | | Triglyceride level lower with increased exercise duration (p<.05).
Giovannini, 1992 ^148^ | Schoolchildren in 2 small towns near Milan, Italy | 361 | To investigate how levels of pediatric lipoprotein are influenced by nutritional and familial factors in a northern Italian population. | Family history: Parent report of 1st and 2nd degree history of atherosclerotic complications. | X | NE | NE | Higher TC/HDL-C ratio in the lower quartile of polyunsaturated fatty acid intake (survey data, no p value reported) | CVD not significant for TC, LDL | TC: higher for obese girls (p<0.01) | NE | NE
| | | | Anthropometric: weight ≥ 20% of ideal labeled as obese | | | | | Hypercholesterolemic parents: associated with higher TC and LDL, although not predictive of TC>200 mg/dl or LDL >120 mg/dl. | TG: higher for obese girls and boys (p<0.01)
| | | | 3-day diet record | | | | | Family history of CVD: | HDL-C: lower for obese girls (p<0.001)
| | | | Blood samples: TC, HDL-C, TG, ApoB, ApoAI. | | | | | Sensitivity TC>200: 0.19, LDL>140: 0.09 | LDL-C: higher for obese girls (p<0.001)
| | | | LDL calculated by Friedwald's formula. | | | | | Specificity: 0.83, 0.91 | ApoB: higher for obese girls (p<0.001) and boys (p<0.1)
| | | | | | | | | + predictive value: 0.34, 0.30 | ApoA1: not significant
| | | | | | | | | - predictive value: 0.69, 0.69 | LDL-C/ApoB: lower in obese boys (p<0.1)
| | | | | | | | | of Family history of HC:
| | | | | | | | | Sensitivity 0.22 0.13
| | | | | | | | | Specificity 0.85 0.93
| | | | | | | | | + predictive value:0.47 0.52
| | | | | | | | | - predictive value: 0.65 0.65
| | | | | | | | | Family history of CVD + HC:
| | | | | | | | | Sensitivity 0.20 0.11
| | | | | | | | | Specificity 0.86 0.93
| | | | | | | | | + predictive value: 0.61 0.64
| | | | | | | | | - predictive value: 0.48 0.48
Glassman, 1993 ^149^ | Retrospective chart review of 98 children referred for evaluation and treatment of obesity or Type IIA hyperlipoproteinemia at the Children's Nutrition Center, NY Medical College. | 98 | To determine whether inclusion of obesity to the current AAP criteria significantly enhances their predictive value in identifying children with hypercholesterolemia. | Family history: obtained from medical record | X | NE | NE | NE | NE | Obesity defined as BMI 20.5 or body weight >120% of ideal. 36/45 (80%) obese children had cholesterol levels >90th percentile (suggesting > risk for hypercholesterolemia in this group). If obesity was added to AAP criteria, 66/80 hypercholesterolemic subjects would have been identified. This would also improve sensitivity of the standards (70 vs 87%, p<0.02) and negative predictive value (45 vs 30%, p<0.02) | NE | NE
| | | | Anthropometric measures: BMI, percent ideal body weight [(actual weight/height appropriate weight)×100]. Obesity defined as BMI 20.5 or body weight >120% of ideal. | | | | | | BMI and percent ideal weight not correlated with TC/LDL-C in obese subjects.
| | | | Venous blood samples after 14 hour fast: TC, TG, HDL-C. LDL-C calculated as difference between TC and HDL-C. | | | | | | BMI inversely correlated with TC (p<0.005) and LDL-C (p<0.002) in non-obese, hypercholesterolemic patients.
Gliksman, 1993 ^174^ | Healthy Australian schoolchildren aged 12 and 15 (subgroup of 1985 ACHPER sample survey) | 1017 | To report on differences in dietary variables and serum lipids by age, sex, and ethnic origin in a national cohort of Australian children. | Anthropometric: BMI | X | NE | NE | In multiple regression analysis, socioeconomic and gender-based lipid differences could be explained by differences in diet. Significant differences of dietary fat intake based on ethnic origin were not reflected in serum lipid differences. | NE | Girls: Dietary fat variables were more important predictors of serum lipids than BMI. BMI negatively associated with HDL. Positive association with TG and LDL/HDL. | In multiple regression analysis, age did not explain socioeconomic and gender-based differences in serum lipids. | NE
| | | | Diet: 24 hour diet record | | | | Girls: Dietary fat variables were more important predictors of serum lipids than BMI. (%kJ saturated fat: TG, HDL; PS ratio: TG, HDL, LDL/HDL) | | Boys: BMI was a more important predictor of serum lipids than dietary fat. TC and HDL: Negative association with BMI. TG and LDL/HDL: Positive association with BMI.
| | | | Blood sampling after 12 hour fast with procedures from LRC. TC, TG, HDL. LDL calculated. | | | | Boys: BMI was a more important predictor of serum lipids than dietary fat.(Dietary fat not associated with TC, TG, HDL, LDL, LDL/HDL)
| | | | Socioeconomic status: As linked to postal code.
| | | | Ethnic origin: Determined by parent birth country
Howard, 1991 ^150^ | Children aged 7–18 years in Spokane, WA | 78 | To answer 6 research questions: Is there a difference in:; 1) Physical measurements and different diets; 2) Physical measurements and blood pressures; 3) Physical measurements and parental smoking status; 4) Physical measurements and family history of CD or no CD; 5) Relationships exercise and physical measurements; 6) Physical measurements and Type A personality | Bloomsday Cardiovascular Fitness Questionnaire; Coronary Risk Profile (family history and other demographics); Diet Habit Survey: Type of diet: 1) meat 2) dairy 3) fats and oil 4) grains 5) sweets 6) salt Four classifications of fat intake: American diet (40% from fat), Phase I (30% fat), II (25% fat), and III (20% fat) | Multiple one way ANOVAs | Walk and run: Pearson correlations only | Correlation only | American diet of meat had significantly lower weight percentiles than Phase II diets (p =0.03). | Family history of heart disease and high blood pressure: Chi square tests only | NE | Blood pressure: Mann-Whitney U statistics only | Stress/personality characteristics: No need to excel had higher weight percentiles than those with some, a fair or a great need to excel (p=0.04, p=0.01, p=0.001 respectively). Non-competitive subjects had a higher weight percentile than those who were somewhat competitive or very competitive (p=.0.05, p=0.001 respectively).
| | | | [underlined: Physical measurements]: total serum cholesterol and HDL-C level, weight, and blood pressure | | | | American diet of fat had significantly higher HDL-C percentiles than those in Phase I, II, or III (p=0.001). American grain diet (>13 yrs) had higher cholesterol percentiles than subjects in Phase II (p=0.01). Phase I diet (>13 yrs) higher cholesterol than subjects in Phase II (p=0.01). American grain diet lower weight percentiles than Phase 1 (p=0.01). | | | | Smoking: T-tests only
Jiang, 1995 ^173^ | Bogalusa, LA, 5–30 yr olds (age 5 – 17 reported here ) | 4136 | To assess whether circulating insulin is a major contributor to adverse lipid profiles during the transition from adolescence to adulthood | Serum total cholesterol, triglycerides, VLDL, HDL, LDL, plasma glucose, plasma insulin. | X | NE | NE | NE | NE | NE | Fasting insulin level: + association with VLDL cholesterol independent of age, sex, glucose concentration, obesity, cigarette smoking, and alcohol intake; | NE
| | | | Obesity (skinfold thickness), smoking, alcohol and life style and health habits survey | | | | | | | - association with HDL in whites aged 5 to 17. Although fasting insulin level along with other variables was shown to be a significant predictor of lipoprotein measures, it can account for only a small part of the variability of lipoprotein cholesterol level (R2 values were low).
Jarvisalo, 2001 ^151^ | Males and females ages 8– 14 yrs Non-controls from outpatient clinic of the Department of Pediatrics, Turku University Central Hospital 44 diabetes 16 hyper-cholesterolemia 28 controls | 88 | To examine the feasibility of measuring aIMT in children and to study its value in distinguishing high-risk children from healthy controls compared with a more established marker of subclinical atherosclerosis | Abdominal aorta (aIMT) and carotid artery thickness (cIMT); blood pressure; serum total, LDL and HDL cholesterol; triglycerides; glucose | X | NE | NE | NE | NE | NE | Multivariate regression model results: | NE
| | | | | | | | | | | aIMT associated with group (diabetes and HC) (p=0.001), age (p=0.014), diastolic blood pressure (p=0.75). cIMT was associated with group (diabetes and HC) (p=.0.001) and diastolic blood pressure (p=0.046)
| | | | | | | | | | | No association with serum total, LDL and HDL cholesterol, triglycerides or glucose
Kunz, 2005 ^153^ | Boys with mean age 14.5 recruited from 8 schools in Innsbruck, Austria. | 336 | To compare coronary risk factors of smoking and non-smoking boys; to gather information on whether boys who start smoking early have different baseline charactoristics impacting coronary risk. | TG, HDL-C, TC, gluclose, LDL-C (Friedman's formula), coagulometric and chromogenic assays, radioimmunoassays, blood cell counts. | X | NE | NE | NE | NE | NE | NE | Smoking
| | | | Cardiovascular endurance (PWC-170 bicycle ergometer test), handgrip strength, average weekly hours in sports, forced expiratory vital capacity and peak flow. Self report of medical histoy, sports activities, alcohol consumption, smoking habits of self and parents. | | | | | | | | TC and LDL-C lower in smokers after adjustment for age, size, weight, BMI.
| | | | | | | | | | | | HDL-C: No significant difference between smokers and non-smokers after adjustment for weight or BMI
| | | | | | | | | | | | TG: No difference
Kwiterovich, 1997 ^154^ | Boys and girls with elevated LDL age 8 – 10 at baseline of 3 year study | 663 | To examine the effects of dietary intake of fat and cholesterol, sexual maturation and BMI on LDL-C on boys and girls with elevated LDL-C levels. | Fasting serum LDL-C, total cholesterol, triglycerides, HDL-C, dietary intake, height, weight, Tanner stage. | X | NE | NE | For boys, LDL-C decreased by 0.696 mg/dL for each 10 mg/4.2 MJ decrease in dietary cholesterol (p<.05). For girls, no single nutrient was significant, but there was a treatment group effect (p<.05) | NE | BMI | NE | Sexual development
| | | | | | | | | | For both genders, BMI at 3 years and LDL at baseline were significant and positive predictors of LDL | | Males: LDL lower at Tanner Stage 4+ than Stage 1 (p<.01)
| | | | | | | | | | | | Females: LDL lower at Tanner Stage 4+ than Stage 1 (p<.05)
Larsson, 1992 ^152^ | 7 year old students in Sweden | 147 with family history; 148 controls | To compare lipid measures in 7 year old children who have a family history of myocardial infarction/angina pectoris before age 55 or hyperlipidemia to children without this family history. | Family history: Parents completed a family history questionnaire | X | NE | NE | NE | TC, LDL, LDL/HDL for those with family history of hyperlipidemia vs controls (p<0.001). | NE | NE | NE
| | | | Venous blood samples: Drawn after overnight fast, TC, HDL-C, TG. LDL calculated. | | | | | No difference in these lipids among those with family history for myocardial infarction or angina pectoris exclusively vs controls.
| | | | | | | | | HDL, TG: No significant difference between those with any family history vs controls
Macek, 1989 ^155^ | Students aged 16 – 18. Treatment group recruited from high school where 5 hours a day was devoted to swimming and athletics. Controls, recruited from a similar school, had lower activity levels, were 1.7 years older and similar in height and therefore viewed as comparable. | 93 | To investigate differences in CHD risk factors in groups of trained and untrained adolescents. | Family history: Parents completed World Health Organization Questionnaire for CHD history. | X | NE | TC: not significant | NE | NE | NE | Gender: Girls had higher HDL-C (p<.001) | NE
| | | | Maximal aerobic power: cycle ergometer following WHO criteria. Anthropometric: percentage body fat. Venous blood samples following overnight fast: TC, HDL-C, LDL-C, Apo-A, Apo-A1, Apo-B, TG. | | | HDL-C higher vs controls (p<0.05); significant relationship with Vo2 max (p<0.001)
| | | | | | | Apo-A1 higher vs controls (p<0.01)
| | | | | | | Apo-A higher vs controls (p<0.01)
| | | | | | | LDL-C lower vs controls (p<0.001)
| | | | | | | Apo-B lower vs controls (P<0.001)
| | | | | | | TG lower vs controls (p<0.001); significant relationship with Vo2 max (p<0.001)
Marti, 1989 ^156^ | 15 year-old boys and girls from 40 Finnish schools | 1142 | To examine the associations between frequency of leisure time exercise and cardiovascular risk factors in adolescents. | Leisure time exercise: self-report using a 5 category question. | X | No relationship between leisure time exercise and TC or HDL. | No relationship between aerobic fitness and HDL or TC. | NE | NE | HDL: Inversely related to BMI for boys and girls (p<0.01) and sexual maturation for boys (p<0.01). | NE | Smoking: Inversely related to HDL for boys (p<0.01) and girls (p<0.05)
| | | | Aerobic fitness: Self-report of distance covered during 12 minute run.
| | | | Anthropometric: BMI, Tanner scale for sexual maturity
| | | | Blood samples: serum TC, HDL, serum thiocyanate.
| | | | Smoking measured by self-report in 13 questions
Muhonen, 1994 ^120^ | 9th through 12th grade students aged 14 to 20 in Muscatine, LA. | 599 | To determine the utility of a school-based family history questionnaire to identify adolescents with adverse coronary risk factor levels. | Family history: HFTQ questionnaire, history of heart attack, angina, bypass surgery, hypertension and obesity; morbidity and mortality in parents and grandparents | X | NE | NE | NE | Parent history of CHD: >BMI, <ApoA1 | NE | NE | NE
| | | | Anthropometric measures: TSF thickness | | | | | Grandfather history of CHD: <ApoA1, >HDL, >BMI
| | | | Venous blood samples after overnight fast: TC, HDL, TG. LDL calculated | | | | | Grandfather history of high cholesterol: >TC, >LDL, >ApoB, >LDL/HDL ratios
| | | | | | | | | Grandmother history: Not significant
Raitakari, 1996 ^157^ | Finnish children and adolescents aged 3–18 years, pulled from the national population register | 714 | To analyze the effect of changes in physical activity and other determinants of HDL-C on HDL-C levels. | Physical activity index: questionnaire of leisure-time physical activity using intensity X estimated duration X monthly frequency, the range was 0–225. | X | Boys: HDL-C was significantly correlated with physical activity, with a correlation coefficient of 0.20 (p<0.001) | NE | NE | NE | Changes in subscapular skinfold thickness correlated to changes in HDL-C for both boys and girls (p<0.05 for both). | NE | NE
| | | | Anthropometric measures: subscapular skinfolds, height, and BMI. | | Girls: Physical activity did not significantly correlate with HDL-C. | | | | BMI change was correlated with a change in HDL-C for girls only (p<0.001), BMI cut-off not defined.
| | | | Smoking: self-report of smoking status and frequency.
| | | | Blood samples: serum total cholesterol, triglycerides, high-density cholesterol, and insulin.
Resnicow, 1993 ^158^ | Data obtained from Know Your Body school health promotion program 1984 - 1991, including 29 elementary schools in 8 states. | 11,370 | To examine the relationship between BMI, systolic blood pressure (SBP), and total plasma cholesterol along with the implications of using obesity as a criterion for blood pressure screening in an ethically diverse sample of 11,370 schoolchildren. | Anthropometric: Quetelet's BMI (kg/m2) | X | NE | NE | NE | NE | 26% of subjects with BMI's in the top decile and elevated SBP had TC levels ≥ 200 mg/dL. This was approximately twice the rate of high TC observed among overweight children with normal SBP (14%), normal-weight children with normal SBP (11%), and normal-weight children with elevated SBP (13%). | NE | NE
| Convenience sample; half of schools from low-income, inner-city neighborhoods. | | | Blood samples: Non-fasting finger-stick. TC. High TC defined as 200mg/dL
Ribeiro, 2004 ^159^ | Healthy, treatment-free children aged 8 to 15 in 17 primary and 13 high schools an urban and rural area of Porto, Portugal. | 1533 | 1) To determine the coexistence of CVD risk factors high blood pressure (HBP), percentage of high fat body mass (%HFM), and high total cholesterol (HTC); 2) To study the relationship between physical activity (PA) and biological risk factors clustering (HBP, %HFM, HTC). | Activity: Physical activity index (PAI) self-report questionnaire on activities ≥ 15 minute duration in past week. Intensity catagories based on metabolic equivalents. Risk factor: ≤ 25th percentile of PAI adjusted for age & sex. PAI divided into quartiles. | X | PAI and percent of subjects with biological risk factors | NE | NE | NE | Percentile high fat mass and HBP: Highest observed odds ratio for clustering. Females: OR 2.6, CI 1.8–3.8 Males: OR 1.9, CI 1.3–2.8. | About half of subjects had ≥ 1 biological risk factor. | NE
| | | | Anthropometric: BMI, tricipital skinfold, subscapular skinfold, percentage fat mass (%FM) estimated via Slaughter, et al (skinfold and maturational stage measurements). Risk factor | | Male: PAI 1st quartile, 59.1% had risk factors, 4th quartile, 41.3% had risk factors (p=0.010) | | | | Percentile high fat mass and high TC: No significant clustering. | HTC and HBP: Clustering significant in females (OR 1.6, CI 1.0–2.4)
| | | | HFM: above 75th percentile for age and sex. | | Female: Not significant.
| | | | Blood: Capillary samples from earlobe after ≥ 12 hour fast for plasma TC. High TC (HTC): ≥ 75th percentile adjusted for age, sex. | | PAI quartiles and 1 and 2 – 3 biological risk factors: no statistical significance.
| | | | Blood pressure: Systolic and diastolic measured in right arm. Risk factor HBP: SBP or DBP ≥ 75th percentile adjusted for age, sex.
Shear, 1985 ^160^ | Children aged 5 to 17 residing in Bogalusa, LA, and their biological parents. Part of the 4th cross-sectional survey of the Bogalusa prospective cohort study. | 3312 | To assess the relationship between parental history of vascular disease (heart attack, stroke, diabetes mellitus and hypertension) and risk factors variables for cardiovascular disease in their offspring. | Family history: Parent or guardian self-report on questionnaire | X | NE | NE | NE | Multivariate analysis: No significant effect for a single parental vascular disease. | NE | NE | NE
| | | | Venous blood samples: 12 hour fasting. TC, TG, LDL, VLDL, HDL | | | | | Combination of parental heart attack with parental diabetes (p<0.0001) and parental heart attack with parental hypertension (p<0.01) significant in relationship to overall risk factors in children.
| | | | | | | | | Risk factors: TC, TG, LDL, HDL, blood pressure
Simon, 1995 ^161^ | Premenarchal Black and white girls aged 9 and 10 in Richmond, CA; Cincinnati, OH; and Washington, DC | 1397 | To determine the correlates of serum HDL-C in 9 and 10 year old girls. | Activity: Television viewing per week | X | Not significant after multivariate adjustment for television viewing and pubertal maturation. | NE | Ratio of polyunsaturated fat/saturated fat intake and polyunsaturated fat/monosaturated fat intake as well as total fat intake showed no significant association with HDL in multivariate analysis. | NE | Changes in subscapular skinfold thickness correlated to changes in HDL-C for both boys and girls (p<0.05 for both). | NE | NE
| | | | Anthropometric: BMI. Sum of skinfolds (triceps, subscapular, suprailiac). Tanner staging for sexual maturation. | | | | Polyunsaturated fat intake associated with higher HDL (p<.05). Each 10% > in polyunsaturated fat intake was associated with > of 3.4 mg/dL. | | BMI change was correlated with a change in HDL-C for girls only (p<0.001), BMI cut-off not defined.
| | | | Diet: 3-day diet record
| | | | Blood sample: HDL
Suter, 1993 ^162^ | Boys and girls aged 10 – 15 recruited from a private school in Calgary. | 97 | 1) To describe lipid levels, physical activity, fitness and diet of healthy Canadians aged 10 – 15. 2) To evaluate if predictive power of physical activity for serum lipid levels exists for this population as it does in adults. 3) To adjust the relationship between activity and blood lipids for confounding factors. | Activity: 7-day recall with metabolic equivalents (MET) and additive 7-day physical activity index (PAIND) calculated. | X | Multiple linear regression analysis: significant predictor for HDL-C, Apo A-1, TG and VLDL-C. | Cardiovascular fitness not significant for TG, HDL, VLDL. | Multiple linear regression analysis: dietary fat intake not a predictor of TG, HDL, VLDL. | NE | Multiple linear regression analysis: BMI not significant predictors of TG, LDL, VLDL. | NE | Alcohol: 7/97 reported use, all in very small amounts. No statistical significance. Smoking: No subjects smoked.
| | | | Substance use and oral contraceptives: assessed in private interview with trained counselor. | | | | | | Gender is a modifying factor of the relationship between subcutaneous body fat and TG or VLDL-C levels. | | Oral contraceptives: No subjects used.
| | | | Cardiovascular fitness: submaximal test using bicycle ergometer. Anthropometric: obtained by 1 measurer with high reliability; sum of skinfolds and BMI included. Diet: analysis of 3-day food records. Venous blood samples after overnight fast: TC, TG, VLDL-C, LDL-C, HDL-C, Apo A-1, Apo B, lipoprotein (a). | | | | | | Bivariate analysis: High sum of skinfolds more closely related to an unfavorable lipid profile in girls than boys.
Thorland, 1981 ^163^ | 8 – 11 year old boys recruited from elementary schools and sports clubs in Ann Arbor, MI. | 55 | Compare lipid levels of pre-adolescent boys who have high or low intensity of physical activity and high or low levels of body fatness. | Activity: 5-day records with time-motion analysis. Parents observed or got information from children on activities and intensity. | X | HDL/TC ratio larger in more active vs less active boys (p<0.05). | NE | Not significant | NE | Body fatness not significant. | NE | NE
| | | | Anthropometric: Skinfold measurements at 6 sites, underwater weighing to assess relative fatness, fat weight, and lean body weight. Diet: 5 day record. Parents recorded food items and amounts consumed by child each day. | 2-way ANOVA and stratification | Triglyceride lower in more active boys (p<0.05).
| | | | Consumption away from home based on child report. Venous blood samples after overnight fast and 36 – 40 hours after exercise: TC, TG
Tolfey, 1999 ^164^ | Healthy 10 year old boys and girls in England | 71 | To identify independent contributions from predictor variables of habitual physical activity, peakV02, percent body fat, and dietary composition are related to prepubertal children's lipid-lipoprotein profile. | Activity: estimated through 4-day continuous heart rate measurement of cardiovascular stress. | X | Girls: Habitual physical activity (HPA) related to lipid-lipoprotein profile (p<0.05) (Bivariate analysis). 1 of 3 main predictor variables for girls in multiple regression analysis, accounting for 18% of unique variance in TC and 22.6% in LDL. | Girls: VO2 related to lipid-lipoprotein profile (p<0.05) in bivariate analysis. | Girls: Polyunsaturated-saturated fatty acid ratio accounted for 10.3% of LDL-C variance and 7.9% of TC/HDL-C variance | NE | Multivariate analysis: | NE | TG: Higher in girls (p<0.01) than boys, and the only gender difference in lipid-lipoprotein profile.
| | | | PAHR-25 (Total time spent 25% above resting heart rate), PAHR-50 (50% above heart rate) and mean heart rate over collection period. | | Boys: HPA related to TC/HDL-C and LDL-C/HDL-C (p<0.05 for both) in bivariate analysis. | Multivariate analysis: | Boys: TC: Daily energy intake accounted for 15.4% of variance and 22% of LDL variance | | TC: % body fat accounted for 12.1% of unique variance, girls only
| | | | Cardiovascular fitness: Peak VO2 measured from cycle ergometer test to volitional exhaustion with expired air collection. | | Not significant in multiple linear regression. | in TG: VO2 accounted for 22.7% of unique variance | | | LDL: % body fat accounted for 21.2% of unique variance, girls only
| | | | Anthropometric: Skin fold, body mass, estimated percent body fat. Sexual maturity assessed by parent and child responses to Tanner drawings. | | | in HDL-C: accounted for 24.8% of unique variance | | | Boys: % body fat not significant
| | | | Diet: 7-day diary completed by parent | | | in LDL-C/HDL-C: accounted for 22.5% of unique variance
| | | | Venous blood samples: Following 11–12 hour fast and no structured exercise 48 hours prior to sampling. TC, TG, HDL-C, , VLDL-C, LDL-C, TC/HDL-C and LDL-C/HDL-C derived from concentration. NCEP performance criteria met. | | | in TC/HDL-C: accounted for 24.2% of unique variance
| | | | | | | Boys: Not significant
Tonstad, 1995 ^165^ | Boys and girls aged 6 to 16 with heterozygous FH in Norway referred to lipid clinic or identified through screening families with known FH. FH diagnosis: LDL receptor mutation or 1 prior TC >6.7 mmol/L and if a parent had tendon xanthomas and/or TC ≥ 7.8 mmol/L with triglyceride levels <3.0 mmol/L prior to treatment with lipid-lowering drugs. | 164 | To compare lipid levels and family history of premature cardiovascular disease in children with FHC210G, null alleles, or no detected mutation, while taking into account parental lipid levels, apoE polymorphism, and anthropometric and dietary characteristics. | Family history: Parental history of cardiovascular disease based on hospital or physician report. Parental lipid levels before treatment obtained from charts. History of early cardiovascular disease in 2nd degree relatives based on family report. | X | NE | NE | Boys: LDL correlated with 24-hour recall cholesterol intake (p=.04) | Multiple regression analysis: LDL related to FH parent's cholesterol levels, percent body fat, pubertal stage, and non-FH parent's cholesterol level (p<.01), together explaining 40% of variance in LDL (CI 25%–55%). | Multiple regression analysis: | NE | NE
| | | | Substance use: Those ≥ age 12 asked about smoking in absence of parents. Alcohol use self-reported (age 11+). | | | | TG correlated with 24-hour recall sucrose intake (p=.004) | HDL related to FH parent's HDL and to pubertal stage, explaining 17% (95%CI, 6% – 31%) of variance in HDL. | LDL related to percent body fat.
| | | | Cardiovascular fitness: | | | | | | Boys TG related to percent body fat and percent dietary energy from sucrose
| | | | Anthropometric measures: Sum of skinfolds: triceps and subscapular sites. Percent body fat calculated from sex-specific regression equation with age and sum of skinfolds. Sexual maturation: Tanner scale. | | | | | | Girls TG related to percent body fat, explaining 7% of variance (95%CI, 0.2% – 27%)
| | | | Diet: Dietary instruction following National Cholesterol Education Program guidelines. No specific weight-loss plans. Unexpected 24-hour diet recall at clinic visit, 4-day diet record.
| | | | Venous blood: Samples following 8–10 hour fast. TC, TG, HDL. LDL calculated by Friedwald formula
Twisk, 2001 ^166^ | Subjects were from the longitudinal Amsterdam Growth and Health Study, who ranged in age from 12–15 years at the initial screening and a mean age of 27 years at the final follow-up | 181 | To investigate the development of biological CHD risk factor clustering and to analyze the influence of lifestyle parameters on this clustering | Biological: Blood - 10 ml for cholesterol and HDL-C testing; Other - blood pressure; Skinfold thickness was measured using four skinfolds: triceps, biceps, subscapular, and suprailiac; cardiopulmonary fitness - maximal oxygen uptake relative to body weight | X | Physical activity was inversely related to the clustering score (RR = 0.89, p<0.01) | NE | Heavy alcohol consumption was inversely related to the clustering score (RR = 0.79, p=0.01) but only for males. | NE | Skinfolds and oxygen uptake were significantly related to TC:HDL (p<0.01, p<0.05, respectively). | NE | NE
| | | | Lifestyle: dietary intake - questionnaire of fat intake, carbohydrate intake, Keys-score, and alcohol intake; smoking - questionnaire of amount of tobacco smoked per week; physical activity - time spent on physical activities in relation to school and work, organized & unorganized sports, other leisure time activities, etc were measured during a structured interview. | | | | There was a weak inverse relationship for fat intake (RR = 0.95, p=0.05) and a weak positive relationship for carbohydrate intake (RR 1.05, p=0.05)
Twisk, 1998 ^167^ | Males and females initially age 13. | 181 | To analyze longitudinal relationships between BMI/SSF and biological and lifestyle risk factors for CHD. | Six repeated measurements over 15 years, starting at age 13. | X | NE | NE | NE | NE | TC male: related to SSF (B=0.12, CI 0.07–0.18, p<0.01) | NE | NE
| Participants healthy students in Amsterdam secondary school. | | | Activity: Structured interview assessing total time in activities, with a total weighted activity score covering the 3 months prior. | | | | | | TC female: related to SSF (B=0.07, CI 0.03–0.11, p<0.01)
| | | | Substance use: alcohol use measured by self-report with diet. Smoking behavior questions in separate questionnaire. | | | | | | TC: related to BMI (B=0.05, CI 0.02–0.08, p<0.01). No relationship with lean body mass.
| | | | Cardiovascular fitness: maximal oxygen uptake measured on a maximal test using a treadmill with speed of 8 km/h and increasing slope. | | | | | | HDL and SSF; HDL and BMI; HDL and lean body mass: no significant relationship
| | | | Anthropometric measures: BMI, sum of 4 skinfolds (triceps, biceps, subscapular, suprailiac). Lean body mass [(100-%body fat)×body weight] (body fat estimated from SSF) | | | | | | TC:HDL ratio: related to SSF (B=0.08, CI 0.05–0.12, p<0.01); to BMI (B=0.04,CI 0.01–0.07, p<0.01); no relationship with lean body mass.
| | | | Diet: cross-check dietary history interview
| | | | Venous blood samples: TC, HDL
Twisk, 1996 ^168^ | Subjects were from the longitudinal Amsterdam Growth and Health Study, who ranged in age from 12–15 years at the initial screening and a mean age of 27 years at the final follow-up | 181 | To investigate the relationship between the longitudinal development of TC, HDL, and TC:HDL ratio and the evolution of lifestyle measures. | Biological: Blood - 10 ml for cholesterol , HDL-C, and ratio of TC to HDL-C testing; Skinfold thickness was measured using four skinfolds: triceps, biceps, subscapular, and suprailiac; cardiopulmonary fitness - maximal oxygen uptake relative to body weight | X | Daily physical activity was positively related to HDL levels (p=0.38) | NE | TC is inversely influenced by the ratio of intake of polyunsaturated fatty acids to saturated fatty acids (p=0.001) but is positively correlated with the intake of cholesterol (p=0.002). As well, the key scores are positively correlated with TC levels (p<0.001). TC:HDL ratio was positively correlated with the intake of carbohydrates (p=0.022). Alcohol consumption was positively related to HDL levels (p=0.001) and negatively related to TC:HDL ratio (p=0.005). No other dietary parameters were found to be significant for TC, HDL, or TC:HDL ratio. | NE | NE | NE | Smoking: inversely related to HDL (p=0.007) and positively related to TC:HDL ratio (p=0.003)
| | | | Lifestyle: dietary intake - fat intake, ratio of polyunsaturated fatty acids and saturated fatty acids, carbohydrate intake, cholesterol intake, and alcohol intake; smoking - questionnaire of amount of tobacco smoked per week; physical activity - time spent on physical activities in relation to school and work, organized & unorganized sports, other leisure time activities, etc were measured during a structured interview
vanLenthe, 1998 ^169^ | Initial recruitment from 1st and 2nd grade of a secondary school in Amsterdam, the Netherlands who were invited to participate in a study on growth, development and risk indicators for cardiovascular disease. | 182 | To investigate the association between the change in a central pattern of body fat and blood pressure and lipoprotein levels in healthy males and females age 13 – 27. | Anthropometric measures: Trunk skinfold measurements (subscapular, suprailiac) and extremity measures (biceps, triceps) used to create a subscapular/triceps skinfold ratio (S/T ratio) as an indicator of central pattern of body fat. | X | NE | NE | NE | NE | Males: >S/T associated with < HDL (Beta -0.14, CI -0.24 to -0.05, p<0.05). No association between change in S/T and change in TC/HDL | NE | NE
| | | | Venous blood samples: Non-fasting TC, HDL. Calculated TC/HDL. | | | | | | Females: No significant association between change in S/T and lipoprotein levels (TC, HDL).
van Stiphout, 1985 ^170^ | Residents of a suburban Dutch community aged 5 to 19 who were a subset of those invited to participate in a study of risk factor for cardiovascular disease (EPOZ). | 458 | To identify the distribution and determinants of serum total cholesterol and HDL in children from a general Dutch population. | Activity: Self-report via questionnaire by children over 10 | X | TC: No relationship to physical activity level | NE | TC: No relationship to coffee consumption. | TC: For both fathers and mothers positively related to TC of children (p<0.001 except for males in quartile 2, where p<0.005). | Body weight and Quetelet index: + relationship with TC for males and females > age 15 (p< 0.05). No relationship for those < 15 years of age. | Age: Decrease in total cholesterol between ages 9 and 16 | NE
| | | | Oral contraceptives: Females age 10+ were asked about | | | | | | Body weight: Negative relationship with HDL in males age 15+ (p<0.05 for quartile 3, p<0.01 for quartile 4). | Menarche: No relationship with TC
| | | | Anthropometric measures: Quetelet index (ratio of body weight over height squared). Females age 10+ asked about menstruation | | | | | | Quetelet index: Similar negative relationship as body weight. (No p value given)
| | | | Diet: Self-report via questionnaire. Coffee and alcohol used assessed
| | | | Venous blood samples: non-fasting, TC, HDL of children and parental TC
| | | | Smoking: Children aged 10+ asked about in questionnaire
Ward, 1980 ^171^ | 74 volunteer families from a previous study on cord blood cholesterol. 74 children evaluated at age 2.5 years. | 74 | To identify familial and environmental variables related to cholesterol levels in children at age 2.5. | Child measures taken at age 2.5 | X | NE | NE | Stepwise multiple regression: | In stepwise multiple regression | NE | NE | NE
| | | | Anthropometric measures: Triceps skinfolds | | | | TC: Previous breast-feeding (vs formula), current dietary poly-unsaturated/saturated fatty acid ratio, maternal alcohol and fat consumption, paternal cholesteryl esters, and maternal hemocrit (r=0.53). | TC: related to paternal cholesteryl esters and maternal hemocrit (r=0.53)
| | | | Diet: Mother provided written diet record for child for 3 weekdays. Dietary history and food frequency record obtained for each parent. | | | | Free cholesterol: similar predictor variable set (r=0.52) | Free cholesterol: similar predictor variable set (r=0.52)
| | | | Blood samples: 5-ml cholesterol, hemocrit | | | | Esterified cholesterol of children: predicted by history of breast-feeding, child's current protein and caloric intake, maternal total and esterified cholesterol, and proteinuria during pregnancy (r=0.69). | Esterified cholesterol of children: predictors included maternal total and esterifies cholesterol (r=0.69)
Wong, 1992 ^172^ | Pediatric-office-based cholesterol screening program in 2–20 year old children; 87% white, 4% Hispanic, 2% Asian, 7% other | 1081 | To evaluate the importance of family history factors and television viewing habits of children for hypercholesterolemia. | Total cholesterol, height, weight, blood pressure. Family medical history questionnaire, dietary habits, exercise, TV viewing. | X | Exercise and activities were not associated with cholesterol level status. | NE | Families who used only extra-lean or no hamburger (vs lean or regular hamburger) were more likely to have children with a cholesterol level of 200 mg/dL or higher (RR 2.5, p<.01). Other dietary habits (type of milk, skin or no skin on chicken, etc) were not associated with cholesterol level status. | Family history of a high cholesterol level but not premature myocardial infarction was associated with an increased likelihood of high cholesterol (RR 1.62, p<.05). | BMI not associated with cholesterol level status. | Age and blood pressure level were not associated with cholesterol level status. | NE
| | | | | | Watching 2–4 or >4 hrs of television daily to have cholesterol level of 200 mg/dL or higher (p<.01).

NA = Not applicable, NE = Not evaluated, RR = Risk ratio, X = Indicates that an adjusted analysis is present (sensitivity analysis).

Evidence Table 3. Screening Strategies

Study, year | Venue | N | Laboratory Method | Family History Determination Method & Definition | Screening Results | Cost | Comments
Bachman, 1993 ^175^ | Routine screening via family history questionnaire at pediatric appointments Kaiser Permanente medical Center, ages 2–18 | 1160 children ages 2–18 | Random serum cholesterol test at Kaiser Permanente Regional laboratory using methods approved by the CDC. | Any 1st or 2nd degree relative (parent, sister, brother, uncle, aunt, grandparent) with heart attack, angina or stroke <age 55; and parental high cholesterol | Of 1160 who completed questionnaires, 529 (46%) had positive family history of CHD prior to age 55 or high cholesterol; 369 (70%) of these had a random cholesterol level drawn as recommended. 93 subjects had TC>185mg/dL; 58 of these (62%) completed follow-up testing for lipid panel. Of the 58 who had a panel drawn, 25 (43%) had LDL>126mg/dL and were offered a 3 or 6 week nutrition program. Of the 25, 9 (35%) enrolled in the program. | NR
Bell, 1990 ^115^ | Screening event via schools in Scotsdale AZ | 1140 fifth grade students | Non-fasting capillary blood samples (Autoclix) collected; total cholesterol measured by wet-chemistry methods using three Abbott Vision analyzers. | Survey of parents for: history of heart attach, stroke, angina, high cholesterol, smoking and high blood pressure in child's parents and grandparents. Age at first occurrence for heart attack, stroke, angina | 1201 returend parental permission and family history forms. 34 children were absent or refused testing. 27 samples were hemolyzed or inadequate. Thus, 1140 students had cholesterol samples measured. 25% had TC>185 mg/dL (4.75 mmol/L) and 13% had levels greater than 200 mg/dL (5.2 mmol/L). | NR
| | | | | Family history of parent or grandparent with high cholesterol, hypertension or vascular disease had the highest sensitivity (77%) but lower specificity (24%). Parent or grandparent high cholesterol had sensitivity of 53% and specificity of 62%.
| | | | | The group with negative familiy history included 40% of all the levels greater than 185 mg/dL and 36% of all the levels greater than 200 mg/dL.
Bistritzer, 1995 ^176^ | Hospital-based screening of children of father hospitalized for myocardial infarction < age 40 Israel | 107 children (ages 2–20) of 40 men (age 31–41) and women | Fasting venous samples, IL Monarch analyser | Family history determined from father's histories of MI or CHD (coronary artery stenosis > 70% of 1+ major branches) before age of 40. Fathers were patients particular Israeli hospital. | 3 men died from MI and 3 refused to participate, so 34 men remained. | NR
| | | | | 8 (24%) had normal values.
| | | | | 26 (77%) had 1+ abnormal values including: TC > 6.24 mmol/l, TG > 2.55 mmol/l, LDL-C > 4.42 mmol/l, HDL-C < 0.91 mmol/l. 6 were obese (BMI > 30 kg/m2) 15 mothers (38%) had significant hyperlipidemia (TC > 6.24 mmol/l, TG > 2.55 mmol/l, LDL-C > 4.42 mmol/l, HDL-C < 0.91 mmol/l, or combination). 6 of the mothers were obese.
| | | | | Children' s mean values: TC 4.68 mmol/l, TG 1.40 mmol/, LDL-C 3.00 mmol/l, HDL-C 1.18 mmol/l. Altogether 42% of the children had significant hyperlipidemia (above 95%ile). 1 child was obese (BMI > 27 kg/m^2^).
Boulton, 1979 ^131^ | Screened samples of children various ages taken from a cohort study, a preschool health program, and a school-based screening program | 200 2 year olds; 385 4 year olds; 230 students ages 8–17 | 2 year olds had non-fasting capillary samples; 4 year olds had fasting capillary samples; school children had fasting venous samples | Family history obtained from parents of children with TC and/or LDL >95th percentile for age; early CHD defined as <65 yrs, hypercholesterolemia in a parent was defined as a TC>251.5 mg/dL | Case finding rate was greatest for the older age group: For 2 year olds, 15 were >95th percentile with 12 having family history of early CHD; For preschoolers, 20 had TCD>95th percentile, 9 with family history of early CHD; For primary school, 4 children had TC>95th percentile, 2 of whom had family history of CHD; For secondary school, 7 students had TC>95th percentile of whom 5 had family history information and all had a family history of early CHD. | NR | Population and method differences make comparisons of these three groups (ages 2, 4 and 8–17) problematic)
Davidson, 1989 ^177^ | School-based screening, 4th graders | 420 of 786 invited children participated | Capillary testing, Kodak CT-60 analyzer; repeated with serum test (Reflotron analyzer) for those with TC>200 mg/dL | Sibling, parent or grandparent history of MI, bypass surgery, stroke, diabetes, high blood pressure, smoking and high cholesterol | 33% of children the upper decile of cholesterol levels had a family history of early < age 56 MI in grandparents, none had family history of early CHD in parents. 83% of those asked to return were confirmed to have TC>185mg/dL | Cost <$2 per test.
Dennison 1994 ^133^ | Otsego County, NY population survey | 10,457 children ages 2–19 | N/A | Questionnaire asking household adults >age 20 to completed information about cardiovascular disease, early cardiovascular disease (<age 60) in sibling or parent, history of “high cholesterol” diagnosed by a physician, and whether blood cholesterol was measured in the past 2 years | Most of the family history of early coronary heart disease was not due to coronary heart disease in the parents (only 5.8% had parents with early coronary heart disease). | NR other than, "parents who belonged to an HMO were much more likely to have had their cholesterol levels measured than parents with private group insurance, Medicaid, or no health insurance.
| | | | | Children living in two-parent households were more likely to report a known family history of early coronary heart disease than children living in single-parent households (41.8% vs 25.8%, p<0.001) and twice as likely to have known parental hypercholesterolemia (18.8% vs 9.5%, p<0.001).
| | | | | Authors adjusted their estimate of children qualifying for cholesterol screening in order to account for the younger age (<55 yrs) for definition of early coronary heart disease used by the NCEP. With this adjustment, 29% of children from 2-parent families (reduced from 41.8%), and 18.4% of children from one-parent families (reduced from 25.8%) would qualify for lipoprotein analysis. Overall 38% of this population would qualify for cholesterol screening.
| | | | | 35% of children had incomplete or unavailable family health history and/or unknown parental cholesterol status.
Dennison, 1989 ^126^ | Bogalusa | 2127 children ages 3–17 | Lipid Research Clinic protocol | Questionnaire completed by parent/guardian, asking whether child's natural mother or father had a history of “high blood pressure,” heart attack," “stroke,” or “sugar diabetes.” Four years later a questionnaire asked parent's age at first heart attach for 108 of the 144 parents who had previously reported a history of heart attack. | Only 40% of white children and 21% of black children with elevated LDL levels (>95th percentile) had a parental history of vascular disease. | NR
Diller, 1995 ^117^ | Cincinnati Myocardial Infarction and Hormone (CIMIH) Family Study | 241 families and 501 children ages 2–19 | A singleTC and LDL-C determined in a CDC and NHLBI standardized laboratory. | Screening indicators were: history in parent or grandparent of documented myocaridal infarction, angina, pectoris, peripheral vascular disease, sudden death, angiographically demonstrated coronary artery disease, ballon angioplasty, or coronary bypass grafting before age 56. | Prevalence of screening indicators was 47.8%. | NR
| | | | Discretionary indicators were: HTN, obesity, diabetes, smoking, steroid use, high fat diet. | Prevalence of discretionary indicators was 54.7%.
| | | | | 9.9% had high LDL-C (≥130mg/dL)and 15.1% had borderline LDL-C levels (110–130mg/dL).
| | | | | Of the 58 children with elevated (borderline or high) LDL-C, 7 had no identifiable screening indicators, 38 had at least one of the discretionary indicators.
| | | | | Diet alone would have identified 29 children with elevated LDL-C values.
| | | | | Parental cholestoler concentration >240 mg/dL would have identified 31 children with elevated LDL-C.
Faigel, 1992 ^178^ | Mass screening of college students | 9,938 students ages 17–21 | Students required to submit cholesterol results upon matriculation; those >200 mg/dL (95th percentile approximately) were referred to student health for lipid profile | AAP criteria (heart disease, CAD or stroke prior to age 50) | 427 of the 873 students with cholesterol levels >200 mg/dL completed fasting lipid profile; 344 of these had abnormal levels (TC>200, TG>180; LDL>160 or HDL<30). Others had testing done by their PCP (data not included). 43 of the 344 students with abnormal lipid profiles met AAP criteria with family history of early CHD. | Cost per case identified was $212.
Gagliano, 1993 ^118^ | All new patients at an adolescent/young adult clinic associated with a children's hospital | 224 of 248 new patients participated | Total cholesterol obtained at time of visit; those with TC>185mg/dL (85th percentile) advised to have repeat fasting lipid panel (Kodak Ektachem 700) | Questionnaire administered to patient by physician; positive if any member of the family (1st and 2nd degree relatives) had early myocardial infarction (<50 for men, <60 for women) or elevated lipids; negative if no history or unknown. Parent interviewed if present at clinic visit. | Family history based on adolescent interview had 36.4% sensitivity and 69.1% specificity for hypercholesterolemia (TC>185mg/dL); family history based on parent interview was 65% sensitive and 45.7% specific; combined history was 45% sensitive and 69% specific. | NR
| | | | | Of the adolescents with elevated cholesterol levels, 16 (48%) would have been missed if screening was performed only based on family history (including 1 of 2 patients with cholesterol >240 mg/dL).
| | | | | Of the 33 patients with TC>185 mg/dL, only 13 (39%) returned for fasting lipid profile. Of these 13 patients, 6 had LDL>125 mg/dL, HDL<35, or TC/HDL>4.5.
Garcia, 1989 ^179^ | Routine surveillance of pediatric patients age 3–18 | 6500 ages 3–18 (mean 6.4 years) | Non-fasting venipuncture with Reflotron analyzer, confirmed with fasting lipid profile if >200 mg/dL (95th percentile) | Family history of premature MI or known hypercholesterolemia | 552 (8.5%) had cholesterol > 200mg/dL; Of those 487 completed the fasting lipid profile and 375 had LDL>130 (95th percentile); Of these 42 had LDL>190mg/dL; 90 had LDL between 160–189 mg/dL and 243 were between 130–159mg/dL | NR
Goff, 1991 ^186^ | Routine screening at well-child visits in the office of 4 pediatricians. | Ages 4–19 | Non-fasting capillary bloodsample with Reflotron analyzer | NR | In 12 month period, 138 or 791 boys (18.5%) and 100 of 165 girls (16.3%) had TC screening values that exceeded the 90th percentile for gender. | NR
| | | | | In ther first 6 months, 238 patients were identified. 37% of boys and 38% of girls received follow-up by a second cholesterol check, a lipoprotein analysis or both.
| | | | | Overall, 37.4% of those with sex-sepcific TC > 90th percentile and 43% of those with sex-specific TC >95th percentile had f/u within 6 months
Griffin, 1989 ^119^ | Routine screening of children in pediatric office practices. | 1,005 children ages 2–13 | Non-fasting serum cholesterol: commercial laboratories or physicin offices (desk-top analyzers). | Parent or grandparent with hypercholesterolemia, sudden death, gout, peripheral vascular disease, any family history of obesity. Any family history of coronary artery disease, various combinations. | Using a family hisotry of early coronary arter disease or hhpercholesterolemia (parent or granparent) would have detected 51% of children with elevated LDL-C. | NR
| | | Children with TC>175mg/dL (75th percentile) were asked to return for fasting lipid panel.
Hammond, 1994 ^180^ | Routine screening of children in seven primary schools in Cantebury England selected from a range of socioeconomic backgrounds | 593 | Non-fasting venipuncture | NR | Of 593 consent forms, 443 parents (74.7%) gave positive parental consent. Of the 443, 13 children (2.9%) were absent for the venipuncture, 21 children (4.7%) refused, for 17 (3.8%) there was a technical failure, 2 (.05%) felt unwell or unspecified. Venus sample obtained from 390 (88%). 375 (84.6%) were usable for analysis. | NR | Paper looks at feasibility of testing; no data on levels.
| | 295 (50%) ages 5–6; | | | | | Note significant difference in failure rate of phlebotomists.
| | 298 (50%) ages 8–9 | | | | | Lower parental response rates were from schools with lower socioeconomic backgrounds.
Heyden, 1991 ^181^ | Cholesterol education and screening in 5 North Carolina high schools, ages 15–17 | 1910 tested in 1987 | Reflotron instruments (Boehringer-Mannheim Diagnostics, Indianapolis, Indiana), using a finger stick blood sample | NR | In both males and females, the 2 schools that included teacher involvement had significant decreases in cholesterol levels over a one year period. Males in first school (n= 219) levels decreased from 145.1 to 129.7 (p<0.05). Males in second school (n=261) levels decreased from 151.1 to 131.6 (p<0.05). Females in first school (n=280) levels decreased from 162.7 to 143.3 (p<0.05). Females in second school (n=321) levels decreased from 165.2 to 151.7 (p<0.05). There were no significant differences in the 3 other schools that did not include teacher involvement. | NR | Paper examines methods of cholesterol education. Interventions: teacher involvement plus testing vs no teacher involvement plus testing.
| USA | 1845 tested in 1988 | | | | | Teacher involvement described as: discussing cholesterol, nutrition, heart disease; demonstrated how to read package labels; counseled on cafeteria food choices, follow up discussion after testing, etc.
| | | | | | | Testing occurs first in 1987, then again to evaluate methods in 1988.
Lannon 1992 ^130^ | Routine screening of all children at well-child visits in six-member pediatric practice | 439, ages 2–15 | Capillary testing, Kodack DT-60 analyzer, if high advised to return for fasting lipid panel (LRC approved lab) | NR | Of 439 screened, 134 (31%) had TC>175 or LDL>110 mg/dL (AAP criteria). Of those with abnormal screening tests, 63 (47%) returned for lipid panel; of those returning, 54 (86%) were confirmed to have hypercholesterolemia. Of those 134 children, 23 (17%) had negative family history and thus would have not been screened according to AAP/NCEP criteria. | Cost of lipid profile $13
Lansing, 1990 ^182^ | Mass screening at state fair | 69 people ages 2–19 | Capillary testing, Reflotron analyzer. | Not part of screening program | Well-accepted. 3 found to have moderate risk, 3 to have high risk (not defined) | Cost per person found with elevated cholesterol was $40 (includes adult cases); $140 per person who visited his/her physician.
Manchester, 1989 ^183^ | RCT of mass screening of college students vs. selective screening (all sophomores with family history of heart disease) | 735 of a total 1,117 students ages 17–19. | Non-fasting blood sample, Kodak Ektachem analyzer; confirmed for those with TC>180 mg/dL (75th percentile) | Any relative with CAD or stroke | 735 (62%) of students had cholesterol tested; no difference in family history between those who had cholesterol measured and those who did not, although the aim was to get those with family history. 60 students had confirmatory measurement; 50 remained over 180mg/dL. Only 10% of those with a risk factor chose to participate. | Cost per case confirmed was $121 for mass screening vs $624 for selective screening.
Muhonen, 1994 ^120^ | Mass screening of high school students grades 9–12 in Muscatine, IA | 599 students from a total of 1,024 students, ages 14–20 | fasting venous blood sample, LRC processing methods | Students completed family history questionnaire at home, with help of parents. Family history assessed for parent or grandparent with fatal or nonfatal MI, angina, bypass surgery, HTN, high cholesterol or obesity. Classifications: no CHD, early CHD (between ages 30–55 for at least one parent or grandparent); later CHD (after age 55 in at least one parent or grandparent); and unsure (incomplete forms, missing information or unsure about at least one parent or grandparent. | Of 1,024 targeted students, 599 had both family history questionnaire and lipid measurements completed. 19% indicated a parental history of hyperlipidemia; 26% had unsure responses. 2.5% had a parental history of early CHD. | NR
Polonsky, 1993 ^184^ | Pediatric lipid clinic at Children's Hospital Medical Center, Cincinnati, OH | 182 mean age 9 (18 months – 20 years) | Fasting levels of TC, HDL-C and TG were drawn at the clinic and analyzed at the one central laboratory. | NR | 16 (9%) subjects had normal lipid levels and classifications. Of those (59 subjects, 32%) with elevated LDL-C levels, 16 had concurrent elevated TG or depressed HDL-C. In the TG:HDL-C group (54 subjects) 46 had TG > 95th percentile. For subjects with HDL-C below the 5th percentile, 5 had borderline TG (75th to 95th percentile) and 3 had normal TG levels. | NR
Resnicow, 1993 ^122^ | School-based screening in 4 elementary schools, grades 1–6 | 1166 | Non-fasting capillary samples analyzed with Kodak Ektachem DT 60. | Questionnaire sent home to parents asking them about their cholesterol levels (asked to provide specific value if known) | Using a parental cut point of 200 mg/dL, 34% of children would have been screened. 40.3% and 48.5% of children with TC values >170 mg/dL and >200 mg/dL would have been identified. Using NCEP/AAP recommended parental cut-point of 240 mg/dL, 9% of children would have been screened and 10.3% of children with TC values >170 mg/dL and 200 mg/dL would have been identified. | NR
| | | | | If clinicians screen only children with one parent who reports a total cholesterol≥240mg/dL, between 90–93% of children with elevated total cholesterol (≥170) would be missed.
Rifai, 1996 ^62^ | African American adolescents at the Adolescent medicine and Ambulatory Clinic: 260 of 201 enrolled | 260, ages 12–20 years (74% female) | fasting venous samples, Ektachem 700 analyzer, CDC certified lab. | Questionnaire completed by patients | 37% of population would have met NCEP/AAP criteria for screening. Of 95 patient meeting screening criteria 25 (26%) had LDL>110 mg/dL (75th percentile); 11(12%) had LDL>130mg/dL (90th percentile). 66% of those with LDL>110mg/dL and 60% of those with LDL>130mg/dL would have been missed under current screening guidelines, even including those with unknown family history. | NR
Shea, 1990 ^59^ | Columbia Study of Childhool Activity and Nutrition (recruited mainly from General pediatrics Group Practic at Presbyterian Hospital, New York). | 108 Hispanic children who had lipids measured | fasting venous blood samples analyzed for TC and HDL-C and TG in a Columbia University research laboratory calibrated to Centers for Disease Control standards. | Positive if child's mother had HTN, diabetes, obesity, hyperlipidemia or family hsitory of premature CHD or hyperlipidemia. No data on risk factors obtained from the fathers. Also positive if history of hyperlipidemia, premature CHD, MI or sudden death in child's parent or aunt, uncle, or granparents. | Using AAP definition of family history, sensitiviy was 57% and specificity was 59%. When family history defined according to NIH consensus conference and the AHA, senstiivity was 46% and specificity was 70%. | NR
| | | | | 12 of 106 would have been misclassified on the basis of TC level (LDL-C would have placed them in another risk category).
Skovby, 1991 ^185^ | Copenhagen school system | 2085, ages 6–8 | Non-fasting capillary blood sample obtained between 8am–12pm. | Parents completed a questionnaire on incidence of chest pains or coronary occlusions in themselves or their parents, siblings, aunts, uncles including age. Positive family history defined as angina pectoris or myocardial infarction <age 50 in men and <age 60 in women. | 3025 questionnaires distributed, 2657 returned, 2166 consented to screening with capillary blood measurement. | NR
| | | | | Of the 2,657 questionnaires completed, 398 families (15%) disclosed a history of early cardiovascular disease.
Steiner, 1991 ^124^ | Kaiser Permanente Teenage Health Centers in Los Angeles, CA | 1001, 12–21 years old | Random serum cholesterol test performed at one central laboratory. | Questionnaires were completed about risk factors and family history. Used AAP criteria from 1985 and 1988. | Only 30 of 64 (sensitivity = 47%, specificity = 74%) subjects with hypercholesterolemia were identified by the 1985 AAP criteria, while 40 of the 64 (sensitivity = 62%, specificity = 60%) subjects were identified by the 1988 AAP criteria. Combining the two criterias (1985 & 1988 AAP criteria) 44 of the 64 (sensitivity = 69%, specificity = 53%) subjects were identified. | NR
Sveger, 2000 ^79^ | School-based questionnaire, with lipid levels in those who were high risk and their parents, ages 10–11 | 4000 questionnaires; | Blood samples collected after overnight fast from high risk child and parent(s). Centrifugation serum was separated and frozen at -20° C for later analysis. | Family history questionnaire that asked parents whether they or the child's grandparents has suffered premature CAD (before age 50 in father or grandfathers; or before age 55 in the mother or grandmothers). Definition of genetically linked dyslipidemias: 1) LDL-C > 189.48 mg/dL + parent has hypercholesterolemia or died of premature CAD. Hypercholesterolemia in parent = above, or if TC > 290.03 mg/dL + myocardial infarction occurred before age 50 (male) or 55 (female) in first degree relative 2) child has increase of LDL-C + apolipoprotein B, or only apolipoprotein B, and a parent with hypercholesterolemia and/or hypertriglyceridaemia. | Family history of premature CAD in parents or grandparents was identified in 208 families. 182 agreed to participate. Blood samples obtained from 175. | NR
| | 2199 (55%) were returned | | | 89 children had normal tests (LDL-C ≤ 131.48 mg/dL, HDL-C ≥ 34.80 mg/dL, TG ≤ 124 mg/dL, apolipoprotein B ≤ 1.00 g/l, and Lp(a) ≤ 300 mg/l.
| | | | | Of the remaining:
| | | | | 48 had isolated increase in Lp(a).
| | | | | 23 had non-hereditary abnormalities of low LDL or high HDL cholesterol or apolipoprotein B.
| | | | | 15 were suspected to have genetically determined dyslipidaemias or a combination of risk factors: possible familial hypercholesterolemia in 4; possible familial combined hyperlipidemia in 5; hereditary low HDL in 3; combination of high LDL and Lp(a) in 3.
| | | | | Also, possible familial hypercholesterolemia was detected in 8.

Evidence Table 4. RCTS of Treatment

Author, year | Type of Intervention | Type of Study/ Setting | Aims | Duration of Trial | Population/ Setting | Main eligibility criteria | Enrolled | Demographics | Interventions | Outcomes Assessed | Results | Adverse Effects | Comments | Quality Rating
Amundsen, 2002 ^41^ | Diet | Randomized, double-blind crossover | To assess effect of SE-enriched spread on serum lipids, lipoproteins, carotenoids, fat-soluble vitamins, and physiologic variables in children with FH aged 7 – 12 years. | Study period: 25 weeks with run-ins and washouts | Subjects recruited from patient register at Lipid Clinic of National Hospital in Oslo, Norway | Not specifically noted. Implied:; 1 Parent with hypercholesterolemia; 2 Diagnosed with “definite” or “possible” heterozygous FH; 3 Healthy, with no clinical symptoms of hypercholesterolemia | 38 | Mean age: 10.5 ± 1.7 | Exposure: In a double-blind crossover, with two 8-week interventions, 38 children with FH consumed 18.2 ± 1.5 g SE spread/day, corresponding to 1.60 ± 0.13 g SE spread, or a control spread. Blood samples were analyzed at the start and end of each diet period. Subjects consumed a recommended American Heart Association Step I diet during both intervention periods. | Measures: Plasma total, LDL and HDL cholesterol | Main Clinical Outcomes:; 1 Plasma LDL decreased by 10.2% (p=0.003) with treatment vs control.; 2 Total cholesterol and apolipoprotein B concentrations decreased by 7.4% (p=0.007 and p=0.020, respectively) with treatment vs control.; 3 No changes with treatment in HDL, triaclglycerol or apolipoprotein A-I.; 4 Serum concentration of lipid-adjusted lycopene decreased by 8.1% (p=0.015) with treatment, with no other carotenoid changes.; 5 Lipid-adjusted retinol and a-tocopherol concentrations increased by 15.65% (p<0.001) and 7.1% (p=0.027), respectively.; 6 Alaninetransaminase increased with treatment, which was explained by a significantly lower starting concentration in the treatment vs control period. | ALT increased in SE diet 16.8% (p = 0.04). No subjects had plasma concentration of ALT outside the reference concentration at any time. Starting concentration of ALT was significantly lower in the SE diet period compared to control. | Small N | Fair
| | Oslo, Norway | | Two 8 week treatment periods. | | | 2 non-study-related drop-outs; 1 drop out because the amount of spread required to be consumed was too large. | 50% female | | Triacylglycerol apolipoprotein (apo) A-1 and apo B | | Serum levels of lycopene and B-carotene decreased with SE. After adjustment for lipid changes, differences in B-carotene disappeared; lypocene concentration was still 8.1% lower (p=0.015) in SE compared to control. | Many children used supplements or vitamins during the study.
| | | | | | | | Cholesterol (mmol/L) total: 7.01 ± 1.26 | | Serum concentrations of carotenoids, retinol, and a-tocopherol | | Serum levels of retinol were higher in SE, and after lipid standardization: 15.6% (p<0.001) higher than control. | These variables were not analyzed separately.
| | | | | | | | LDL: 5.39 ± 1.42 | | Blood analyses | | After lipid standardization, ) a topopherol was 7.1% higher in SE than in control (p=0.027). Authors note results may be influenced by different starting concentrations in SE spread than control. | FH was confirmed by mutation analysis in only 25/38 subjects.
| | | | | | | | HDL: 1.37 ± 0.32 | | | | | Some included children may not have had FH, as baseline total and LDL cholesterol concentrations were significantly higher in the confirmed FH group.
| | | | | | | | Triacyglycerol (mmol/L) 0.56 ± 0.22
Becque, 1988 ^221^ | Diet and exercise combination | RCT of exercise, diet and behavior change. | To determine the incidence of coronary heart disease risk factors and the effects of a 20 week diet and exercise intervention program on risk factors including serum lipids. | 20 weeks | Recruited via advertisements in local newsletters and newspapers. | Inclusion criteria: | 36 obese adolescents randomly assigned to three groups: diet plus behavior (n=11), exercise plus diet and behavior change (n=11) or control (n=14). | Girls (n-21): | Control group was encouraged not to change their basic lifestyle | TG, HDL, TC systolic and diastolic BP body weight, % fat and maximum to uptake | Results in mg/dL and reported as mean+SEM post treatment vs post-control. When NS stated means even within group changes were not significant. | NR | | Fair
| | Michigan | | | | 1 Body weight and triceps skinfold greater than the 75th percentile according to NHANES data | | mean age 12.8+0.3 year. | Diet plus behavior change: subjects met with dietician and behavior therapist once/week. Moderate dietary restriction based on ADA exchange program with caloric intake set to elicit the loss of 0.45–0.90 kg/week (1–2 lbs/week). | | Control group (n=14):
| | | | | | | | Height 156.3+1.5 cm | Behavioral treatment included record keeping stimulus control, changing topography of eating and reinforcing altered behavior. | | TG increased 117.8+15.8 to 122.2+13.6, NS
| | | | | | | | weight 71.3+3.6 kg | Exercise plus diet and behavior change: diet and behavior were same as above, exercise program was 50 minutes 3 days/week. Each session included warm-up and aerobic activity, increasing from 15–40 minutes per session of the course of the fist 7–8 weeks. HR maintained at 60–80% of age-predicted maximum. | | HDL increased 29.5+1.6 to 32.0+1.5, NS
| | | | | | | | boys (n=15) | | | TC decreased 1776.9+10.7 to 167.1+9.0, NS
| | | | | | | | mean age 12.7+0.05 year. | | | Exercise, diet and behavior change group (n=11)
| | | | | | | | Height 157.4+2.3 | | | TG: decreased 135.8+16.5 to 91.6+18.4, NS
| | | | | | | | weight 70.8+4.7 kg. | | | HDL increased 35.3+2.3 to 43.4+2.2 (p<0.05 for within group difference, P<0.05 for between group difference in post-intervention levels).
| | | | | | | | | | | TC decreased 170.6+10.2 to 149.3+9.2, NS
| | | | | | | | | | | Diet and behavior change group (n=11)
| | | | | | | | | | | TG decreased 117.3+13.9 to 99.9 +17.4, NS
| | | | | | | | | | | HDL increased 34.5+2.7 to 38.4+3.0, NS
| | | | | | | | | | | TC decreased 181.2+12.3 to 171.9+11.4, NS
Boreham, 2000 ^230^ | Exercise | RCT of stair climbing. | To evaluate the effects of a 7 week progressive stair-climbing program on cardiorespiratory fitness and lipid levels in young women | 7 weeks | Previously healthy female student volunteers ages 18–22, sedentary but previously healthy. | Responded that they exercised or played sport on one or no occasions each week. Students at the University of Belfast. | 25 people enrolled; data reported on 22 women who completed the study. | 22 females, ages 18–22 | Stair-climbing group underwent a 7 week program, progressing from one ascent/day in week 1 to 6 ascents/day in weeks 6–7 on a public access staircase Monday–Friday. Staircase was 199 steps with a total vertical displacement of 32.8 meters. Subjects were instructed to distributed their efforts evenly over the working day and to log completed ascents (ie: could be done in separate short bursts). | 1 Serum lipids; 2 Cardiorespiratory fitness (VO2 maximum and HR); 3 Anthropometry | Pre-post results in mmol/L, mean + SEM after 7 weeks | None reported | 3 subjects (2 controls and 1 stair climber) withdrew because of illness or academic pressures. | Poor
| | Belfast, Ireland | | | | | | | Completed ascents were 75% of the target over the 7 weeks period. | | Stair climbers:
| | | | | | | | | Control group was asked to maintain their normal lifestyle over the experimental period. | | TC decreased 4.93+0.25 to 4.53+0.24, p<0.05 within group
| | | | | | | | | | | HDL increased 1.24+0.09 to 1.48+0.14, p<0.05 but p<0.01 for interaction between groups and p<0.05 for pre-intervention differences between this group and the control.
Clauss, 2005 ^38^ | Drug | RCT | NR | 24 weeks | Post-menarchal girls with heFH | HeFH; baseline LDL required was 160–400 mg/dL and parental history of familial hypercholesterolemia. | 54 girls ages 10–17 at least 1 years post-menarche | 54 girls ages 10–17 | Lovastatin 20 mg for 1st 4 weeks, then 40 mg thereafter | Serum lipids, apo-B | Mean % change from baseline at week 24 in ITT population: | “Adverse reactions to lovastatin were generally mild and transient.” Patients treated with lovastatin had an adverse experience profile generally similar to that of patients treated with placebo. In this limited controlled study, there was no detectable effect on menstrual cycle length in girls. Adolescent females should be counseled on appropriate contraceptive methods while on lovastatin therapy." | Unpublished data from lovastatin package insert and confirmed through contact with Merck, Inc. | Fair
| | | | | | | | | | | TC: -22.4 for lovastatin vs +3.6 for placebo
| | | | | | | | | | | LDL: -29.2 for lovastatin vs +2.5 for placebo
| | | | | | | | | | | HDL +2.4 for lovastatin vs +4.8 for placebo
| | | | | | | | | | | TG: -22.7 for lovastatin vs -3.0 for placebo
| | | | | | | | | | | Apo B: -24.4 for lovastatin vs +6.4 for placebo
Couture, 1998 ^66^ | Drug | RCT Laval University | To determine whether the nature of the LDL receptor mutation effects the response to simvastatin. | 6 weeks | FH patients at university research clinic | 1 Heterozygous FH patients with 1of 3 mutations in the LDL receptor gene.; 2 Aged 8 – 17; 3 Weight ≥ 27 kg; 4 Plasma levels persistently above 95th percentile for age and sex while maintaining a lipid-lowering diet.; 5 No concomitant conditions, such as diabetes, anorexia, thyroid disorders | 63 | 37 boys and 26 girls | Individual screening with medical history, physical exam, interview with dietician, and blood sampling 6 weeks prior to study entry. All lipid-lowering medications discontinued at screening entry. Four weeks placebo run-in, followed by randomization to double-blind active treatment, 20 mg/d simvastatin or placebo for 6 weeks at 3:1 ratio. Compliance verified by tablet count at weeks 0, 2, 4, and 6. Patients questioned about adverse or unusual signs or symptoms at all clinic follow-up visits (weeks 0, 2, 4, and 6). Patients counseled by dietician to follow American Heart Association phase I diet throughout trial. | Total Cholesterol | Compared to placebo, drug reduced total cholesterol, LDL, and total apoB levels at all time measurements (p<0.0001). HDL levels increased in all groups with drug versus placebo (p=0.003 to 0.30), and triglyceride levels decreased (p=0.009 to 0.10). Multiple regression analyses suggested that 42% of the variation of LDL response to drug is due to variation in the mutant LDL receptor locus, apoE genotype, and BMI; 35% of variation in HDL response was due to gender and baseline HDL level. | None reported | Small sample size | Fair
| | Lipid Research Clinic, Quebec City, Canada | To describe the different responses to simvastatin of plasma lipids, lipoproteins, and apoprotein levels among 3 genetically differentiated groups of heterozygous FH children and adolescents. | | | | | Aged 8–17, mean 12.55 | | HDL cholesterol
| | | | | | | | | | LDL cholesterol
| | | | | | | | | | apoA-I
| | | | | | | | | | apoB
| | | | | | | | | | apoE genotypes triglycerides
| | | | | | | | | | BMI
Davidson, 1996 ^67^ | Diet | Double-blind, randomized cross-over study | To investigate the hypocholesterolemic effect of psyllium-enriched cereal in children with documented hyperlipidemia. | 6 weeks of treatment in each condition | Children aged 6 – 18 with in the Chicago area with hypercholesterolemia recruited by family screening and public appeal. | 1 Males and premenarcheal females aged 6 – 18.; 2 LDL > 90th percentile for age and sex at baseline.; 3 Height and weight ≤ 75th percentile; 4 No chronic medical condition, such as diabetes.; 5 Triacylglycerol ≤ 300 mg/dL; 6 Any lipid-lowering agents, including dietary fiber supplements, discontinued ≥ 6 weeks before 1st qualifying blood draw | 25–32 randomized ; 2 dropped due to inability to consume amount of cereal required, 1 discontinued for noncompliance, 2 discontinued for family problems. Of the 27 who completed study protocol, 2 excluded from analysis because baseline LDL varied markedly | 25 children, ages 6–18. | 8 week NCEP diet stabilization followed by blood sampling and random assignment to active or control cereal for 6 weeks. 6 week wash-out, then 6 week crossover treatment period. | Fasting lipid profile (baseline, ever 6 weeks, week 19) | Psyllium cereal vs control reduced total (12.1 mg/dL, p=0.03) and LDL cholesterol (10.9 mg/dL, p=0.01). LDL-cholesterol decreased 7% in active vs control groups. | None reported. “Only one child complained of gastrointestinal effects with slight abdominal bloating” | 8/25 subjects who completed the study were < 80% compliant during 1 or both treatment periods. | Fair
| | | | (8 weeks diet stabilization, 6 weeks treatment 1, 6 weeks wash-out, 6 weeks treatment 2) | | | | Gender and mean age not reported, although females were premenarchal. | Active: 58 g of psyllium-enriched cereal daily. Each serving had 3.2 g soluble fiber. Control: matching placebo cereal without psyllium. Subjects instructed to consume two 28-g boxes of cereal daily for a total daily dose of 6.4 soluble fiber from psyllium. Dietary compliance assessed by cereal box count every 3 weeks, questioning of children individually and with parents, and by 3 day dietary records. Subjects on NCEP diet throughout study. | Compliance assessment | Response to treatment differed between subjects consuming psyllium during period 1 vs period 2. A period-by-time interaction was found for total cholesterol (p=0.02). Subjects consuming psyllium had an average decrease in total cholesterol of 19.1 mg/dL during the 1st period and 5.6 mg/dL during the 2nd period; LDL decreased 17.1 mg/dL during the 1st period and 5.2 mg/dL during the 2nd period. | | Response to treatment differed between subjects consuming psyllium between period 1 and 2.
| | | | | | | | | | Dietary assessment (including computerized nutrient analysis at weeks -8, -1, 6, 12, and 19) | | | Small sample size.
de Jongh, 2002 ^69^ | Drug | Double-blind, placebo controlled multi-center RCT 9 international sites | To evaluate LDL-cholesterol-lowering efficacy, overall safety, tolerability and the influence of growth and pubertal development of simvastatin in a large cohort of boys and girls with heterozygous familial hypercholesterolemia (heFH). | 48 weeks of intervention after 4 week run-in | 173 boys and girls with heFH | 1 Age 10 – 17; 2 LDL-C 158.55 – 398.3 mg/dL; 3 Parent with confirmed diagnosis of heFH.; 4 Boys: Tanner stage II or above; Girls: postmenarchal for at least 1 year before study initiation | 173 | 98 boys and 75 girls | After 4 week placebo/diet run-in, randomization to active treatment or matching placebo in 3:2 ratio and stratified by sex. Simvastin (drug) started at 10mg/day and increased at 8 week intervals to 20 and then 40 mg/day for the remainder of the study (period 1, 24 week duration) and for a 24 week extension (period 2). Office visits every 4 weeks. Menstrual cycle monitored throughout study period and Tanner staging used to assess pubertal development. | Total cholesterol, triglycerides, LDL-C, HDL-C, ALT, AST, CK, apoB, apoA-1, adrenal hormones, gonadal hormones, pituitary hormones and FSH. In girls, B -human chronic gonadotropin was measured each visit. | LDL-C reduced at all time points by drug vs placebo (p<0.001). At 24 weeks, LDL-C reduced 38.4% to 125.29 mg/dL in drug vs 1.2% reduction in placebo (p<0.001). Total-C, VLDL-C, and apoB also reduced vs placebo at all time points (p<0.001). TGs reduced at weeks 8, 16 and 48. HDL-C and apoA-1 increased for all weeks, and were only significant relative to placebo at week 24 (p<0.05). No changes in either treatment group noted in either treatment group at week 24 or 48. | No serious adverse effects. In period 1, 1 discontinuation, due to mononucleosis. In period 2, 4.7% of drug vs 3.4% of placebo reported ≥ 1 drug-related clinical AE. (Difference not significant). Total drug group clinical adverse effects included: abdominal pain (3), chest pain (1), flatulence (1), mylgia (2), headache (4), sleep disorder (1), weight gain (1), pruitus (1). Total drug group lab adverse effects: increased ALT (3), increased AST (3), increased CK (1). | 223 assessed for eligibility, 175 randomized - 69 to placebo, 106 to control. 5 of placebo discontinued: 1 lost to follow-up, 2 withdrew consent, 2 for other reasons. 5 of drug discontinued: 1 to mononucleosis, 1 to protocol deviation, and 3 to consent withdrawal. 101/106 drug completed period 1 and 83/106 completed period 2 (78%). 56/69 placebo(81%) completed period 2. | Good
| | | | | | Exclusion: homozygous familial hypercholesterolemia, secondary hyperlipidemia | | | | | | No deleterious effects on growth or pubertal development.
de Jongh, 2002 ^68^ | Drug | RCT with an additional arm of non-FH controls. | To determine whether simvastatins improves endothelial function in children with familial hypercholesterolemia (FH) | 28 weeks; dosage doubled every 8 weeks | HeFH patients ages 9–18 | Children with heterozygous FH as defined by: | 50 heterozygous FH children plus 19 non-affected controls | FH simvastatin group Mean age: 14.6+2 Female gender: 13 (42%) Race: NR. FH placebo group Mean age: 14.6+2.5. Female gender: 11 (50%) Race: NR. | 50 heterozygous FH children randomized to simvastatin or placebo in 3:2 ratio. An additional 19 healthy non-FH siblings also used as controls. | 1 FMD (flow mediated dilitation) of brachial artery at baseline and 28 weeks.; 2 TC, TG, LDL, HDL;; 3 AST, ALT, CK at each visit for safety; 4 Height, weight and BP. | Mean absolute change in FMD was higher in the FH simvastatin group vs FH placebo group: 3.9%+4.3% vs. 1.2%+3.9%, p=0.05. Mean absolute reduction in TC mmol/l (FH simva -2.16+1.04 vs -FH placebo 0.05+1.17, p=0.0001); increase in HDL mmol/l (FH simvastatin 0.05+0.17 vs FH placebo -0.05+0.22, P=0.080); decreased in LDL (FH simva -2.13+0.99 vs FH placebo -0.05+1.06 mmol/l, p=0.0001); and decrease in TG (FH simvastatin -0.19+0.37 vs FH placebo -0.10+0.54 mmol/l, p=0.041). | “In the present cohort, no toxicity or serious adverse or side effects wre reported by the children during the course of this study. However, the duration of the present study is too short to draw conclusions with regard to the saftey of long-term use of simvastatin in children.” | 28 in FH simvastatin group, 22 in FH placebo group, 19 non-FH controls. | Poor
| | USA. | | | | 1 LDL>95 percentile for age/gender;; 2 Documented family history of hyperlipidemia with LDL>95 percentile for age/gender after treatment;; 3 Personal diagnosis by detection of mutation at the LDL receptor gene
de Jongh, 2003 ^40^ | Diet | Double blind randomized cross-over trial | To determine whether prepubertal HeFH children are characterized by impaired endothelial function and whether short-term intervention with plant sterols can improve endothelial dysfunction. | 4 weeks each period, 2–6 week run-in, 6 week wash-out between treatment periods | 41 prepubertal HeFH children between ages 5–12 and 20 non-FH controls. | Children with HeFH selected as follows: | 41 children with HeFH. | mean age 8.2 years | All HeFH children also were on a low-saturated -fat, low-cholesterol diet (step I). | Endothelial function by flow-mediated filation (FMD) at R brachial artery. | Mean+sd in mmol/L for HeFH children randomized to placebo vs plant sterol spread (baseline data are combined for both P and S groups): | “FH children did not report any adverse effects throughout the study.” | Compliance was 97% in both P and S groups based on returned empty tubs of margarine. | Good
| | | | | The Netherlands. | 1) LDL>95 percentile for age and gender;; 2) documented family history of hyperlipidemia with LDL>95th percentile for age and gender prior to treatment or; 3) personal diagnosis of FH by detection of mutation in the LDL receptor gene. | | 20 males, 21 females | | | TC decreased from 7.30+1.51 to 7.06 for placebo vs 6.27+1.12 for sterol group, p<0.001.
| | | | | | Excluded if: girls post-menarchal, boys with Tanner stage later than stage 1, smoking, current use of vasoactive medications or dietary supplements, any other serious illness (HTN, DM). | | | | | LDL decreased from 5.68+1.51 to 5.4±1.137 for P vs 4.58+1.13 for sterol group, p<0.001
| | | | | | | | | | | HDL increased from 1.25+1.25 to 1.29+0.29 in P vs 1.31+0.31 in S, p=0.594.
| | | | | | | | | | | TG increased from 0.74(range 0.46–2.20) to 0.90+0.40 vs. 0.85+0.36, p=0.476.
| | | | | | | | | | | FMD was significantly lower in the FH placebo group than in the healthy controls (7.2%+3.4% vs 10.1%+4.2%, p<0.005) with no difference in baseline vessel size.
| | | | | | | | | | | Among the HeFH children, FMD in the P and sterol treated groups were not significantly different (7.2%+3.4% P vs 7.7%+4.1%, p=0.592). Again, baseline vessel size between P and S were similar.
Dennison, 1993 ^223^ | Drug | randomized cross-over trial of psyllium | To assess whether psyllium was effect at lowering TC and LDL values in children beyond the reduction achieved by diet alone | 4–5 weeks each period with a 2 week wash-out period between | children ages 5–17 with LDL>110 mg/dL already being treated with diet, recruited from Pediatric Lipid Control Center and from private pediatricians in the vicinity. | Children with LDL>110 mg/dL after treatment with diet. | 25 children began the study; 4 did not return for the final blood drawing (3 because of parental difficulties - timing, logistics; 1 boy because he refused to eat the cereal and have his blood redrawn); 1 second blood sample was lost. | 11 males; 9 females | Diet consisted of <30% calories as total fat, <10% as saturated fat and <200 mg dietary cholesterol/day. Total calories enough to ensure adequate growth. | 1 Dietary intake (food diary kept by subjects and their parents); 2 Serum lipid levels; 3 Serum levels of vitamin D, folic acid, vitamin A, vitamin E, calcium, iron, TIBC and transferrin saturation; 4 Height, weight, subscapular and triceps skin-fold thickness | Results for psyllium vs control cereal (also given are results for each group, change from baseline with the control and psyllium cereals separately). Values are in mmol/L, mean +SEM. | One child (a 17 year old girl reported a transient increase in loose stools (3 /day) with the control cereal with resolved with discontinuation and reappeared with a second challenge of the control cereal and resolved post discontinuation. | baseline lipid levels not different significantly for those (n=5) who did not complete the study. | Poor
| | | | | | | | age 11.1+3.8 years | Subjects instructed to eat two 28gm servings (1 0z or 2/3 c each) of the control cereal (5 mg water-insoluble wheat fiber per serving) or the psyllium cereal (3 gm of water-insoluble fiber and 3 game water-soluble fiber per serving). Cereals were similar in appearance and provided by same manufacturer. | | TC decreased by 0.01+0.10, NS | Compliance was 82% for both cereals. | Most families were unaware of which cereal was in use (2/3 of children or parents incorrectly identified the psyllium containing cereal).
| | | | | | | | | | | HDL increased 0.03+0.04, NS
| | | | | | | | | | | TG decreased 0.68+0.32, p<0.05
| | | | | | | | | | | LDL increased 0.10+0.11, NS
| | | | | | | | | | | Serum iron was higher after the psyllium cereal than after the control (92 vs 75 mg/dL, p=0.04).
| | | | | | | | | | | No changes in subscapular or triceps skin-fold thicknesses.
| | | | | | | | | | | Height and weight increased equally during consumption of control and psyllium cereals.
| | | | | | | | | | | None of vitamin or mineral levels tested were lower after the psyllium cereal.
DISC Collaborative Research Group, 1995 ^219^ | Diet | RCT 6 centers | To assess the efficacy and safety of lowering dietary intake of total fat, saturated fat, and cholesterol to decrease low-density lipoprotein cholesterol (LDL-C) levels in children | 3 years | Prepubertal boys and girls recruited from public and private elementary schools, by mass mailings to members of an HMO, and from pediatric practices | 1 Girls aged 7 years, 10 months – 10 years 1 month; boys aged 8 years, 7 months – 10 years, 10 months; 2 Average of 2 screening LDL-C values ≥ 80th and < 90th percentile for age and sex.; 3 No medication or medical condition that could effect growth or blood cholesterol; 4 No behavior problems in child or family likely to reduce adherence; 5 Prepubertal; 6 No plans to move within the 3 study years | 663 (362 boys, 301 girls) | Mean age: boys 9.7 girls 9.0 | Randomized to diet (334) or usual care (329). | Height and serum ferritin levels at 3 years | At 3 years, dietary total fat, saturated fat, and cholesterol levels decreased significantly in the diet group compared to control (p<.001 for all). LDL-C decreased in diet and control groups by 15.4 mg/dL and 11.9 mg/dL, respectively. With adjustment for baseline level and sex and imputing values for missing data, mean differences between the groups was -3.23 mg/dL (95% CI -5.6 – 0.5 mg/dL) (p=.02). | No differences between groups in adjusted mean height, serum ferritin levels, or other safety measures. | Authors state randomization yielded comparable treatment groups, although baseline diet group had lower polyunsaturated fat (p=.03), higher vitamin B6 (p=.04) zinc (p=.02), a higher proportion with household income < $20,000 (p=.002), and scored higher on the Child Depression Inventory (p=.09) | Good*
| | | | | | | | | Diet: Behavioral intervention to promote adherence to a diet providing 28% of energy from total fat, less than 8% from saturated fat, up to 9% from polyunsaturated fat, and less than 75/mg (1000 kcal) per day of cholesterol (<150 mg/day). Family oriented, based on social learning and social action theory. 1st visit: eating pattern assessed and personalized program developed. In the 1st 6 months: 6 weekly and then 5 biweekly group sessions augmented by 2 individual visits of children with their family members. In the 2nd 6 months, 4 group and 2 individual sessions. Years 2 and 3: group individual and maintenance sessions held 4–6 × per year with monthly phone contacts between sessions. | LDL-C, total serum cholesterol levels, triglycerides, HDL-C, dietary assessment, skinfold thickness, body circumferences, and blood pressure at 1 and 3 years. | No differences between groups in adjusted mean height, serum ferritin levels, or other safety outcomes. | Serum ferritin decreased in both groups and the intervention group had slightly lower mean ferritin concentrations than did usual care at year 3 (p=0.08). In both groups, mean ferritin concentrations remained above the 75th percentile for age and sex. | Low drop-out rate
| | | | | | | | | Usual care: Public educational publications on heart-healthy eating provided. Parents informed if child blood cholesterol high - no specific recommendations to see physician given. 3-year lipid results provided, with referral as clinically warranted. | Red blood cell folate, serum zinc, retinol, and albumin at 3 years | | Risk of consuming less than 2/3 of the RDA was significant for vitamin E at all visits (baseline OR: 1.009; year 1 OR: 1.007; year 3 OR: 1.007; p<0.0001 for all visits); for zinc at all visits for boys (baseline OR: 1.004, p<0.05; year 1OR: 1.003, p<0.02, and year 3 OR: 1.004, p<0.003) and girls (baseline OR:1.007, p<0.001: year 1 OR: 1.008, p< 0.0006 and year 3 OR: 1.005, p < 0.003).
| | | | | | | | | | Annual Tanner staging, height, weight and psychosocial assessments
Engler, 2003 ^224^ | Drug | RCT | To determine the effects of antioxidant vitamin therapy and the NCEP-II diet on endothelial functions well as on surrogate biomarkers for oxidative stress and inflammation. | 6 months | Not reported | 1 Children aged 8 – 21 with hyperlipidemia.; 2 FH (LDL >130 mg/DL and a parent diagnosed) or FCH (LDL >130 mg/dL, or triglycerides >150 mg/dL or both, and at least 1 parent presenting with any of these phenotypes).; 3 No systematic illness with or without secondary hyperlipidemia.; 4 No current smoking. | 15 (8 boys, 7 girls). 4/19 19 were excluded due to noncompliance with vitamin therapy. | Not reported | After 6 weeks of adherence to NCEP-II diet, patients randomized to 6 weeks of vitamin C (250 mg) and vitamin E (200 IU) twice daily or placebo. Following 6 weeks of wash-out, patients crossed-over to alternate treatment group for 6 weeks. All followed NCEP-II diet throughout the trial with the support of nutritional counseling. Dietary intake assessed with 3 non-consecutive 24-hour recalls at each visit. Nutrient intake assessed. Compliance with supplements determined through pill counts. Blood and urine samples obtained at baseline and every 6 weeks. | Brachial artery baseline diameter, flow-mediated dilation, cholesterol (total, LDL, VLDL, HDL), triglycerides, lipoprotein, OxLDL antibody titer, OxLDL-E06 levels, ADMA, F2-isoprostanes, C-reactive protein, urinary 8-OH-2′dG, blood pressure, BMI | Antioxidant vitamin therapy and NCEP-II diet improved FMD of the brachial artery compared with baseline (p<0.001) without an effect on biomarkers for oxidative stress (antibodies to epitopes of oxidized LDL, F2-isoprostanes, 8-hydroxy-2′-deoxyguanosine), inflammation (C-reactive protein), or levels of asymmetric dimethylarginine, an endogenous inhibitor of nitric oxide. | None reported | Very small sample size | Poor
| | | | | | | | | | | The primary effect of the NCEP-II diet was an 8% reduction in LDL (p<.001), with no other significant effects of diet or antioxidants on other lipid levels or biomarkers of oxidative stress, inflammation or ADMA. | | No demographic/setting description
Engler, 2004 ^234^ | Drug | Randomized cross-over trial | To determine whether diet (NCEPII) plus placebo or diet plus docosahexaenoic acid (DHA) affects endothelial function in children with FH or FCH. | 6 weeks each pase with 6 week washout period between | Not reported | Children ages 8–21 with FH or FCH. FH characterized by LDL>130mg/dL and parent diagnosed with the disorder. FCH was characterized by elevated levels of LDL (>130 mg/dL) or triglycerides (>150 mg/dL) or both, and a parent presenting with 1 of these 3 phenotypes. | 20 subjects ages 9–19, 12 with FH and 8 with FCH. | baseline BMI for entire group = 21±4; no race data reported | After 6 weeks of adherence to NCEP-II diet, pts were randomized to 6 weeks of placebo or DHA (all continued on diet). | Primary outcome was brachial artery flow-mediated dilation. Secondary outcomes were lipid levels | Cross-over results presented in aggregate. However, the repeated measures anova indicated no main effect or order and no order by phase interaction “indicating that presenting DHA first or placebo first had no effect.” | Not Reported | | Poor
| | | | | | Excluded were those with chorinc systemic illness with or without secondary hyperlipidemia and current smoking. | | | Subsequently, following a 6 week washout period, the groups crossed over. | | FMD increased after DHA supplementation compared to placebo (p<0.012)
| | | | | | | | | | | TC was higher for DHA plus diet compared to diet plus placebo: 297+81 vs. 286+85 mg/dL
| | | | | | | | | | | TC increased for DHA plus diet compared to diet alone: 263+79 vs. 297+81mg/dL (pre-post comparison, not randomzied, p>0.006).
| | | | | | | | | | | LDL was higher for DHA plus diet compared to placebo plus diet: 229±85 vs. 216±98 mg/dL.
| | | | | | | | | | | HDL was lower for DHA plus diet compared to placebo plus diet: 51±13 vs. 52±11 mg/dL.
| | | | | | | | | | | TG were lower for DHA plus diet compared to placebo plus diet: 119±71 vs. 131±94 mg/dL.
Engler, 2005 ^236^ | Drug | Randomized cross-over trial | To determine whether diet (NCEPII) plus placebo or diet plus docosahexaenoic acid (DHA) affects endothelial function in children with FH or FCH. | 6 weeks each pase with 6 week washout period between | Not reported | Children ages 8–21 with FH or FCH. FH characterized by LDL>130mg/dL and parent diagnosed with the disorder. FCH was characterized by elevated levels of LDL (>130 mg/dL) or triglycerides (>150 mg/dL) or both, and a parent presenting with 1 of these 3 phenotypes. | 20 subjects ages 9–19, 12 with FH and 8 with FCH. | baseline BMI for entire group = 21±4; no race data reported | After 6 weeks of adherence to NCEP-II diet, pts were randomized to 6 weeks of placebo or DHA (all continued on diet). | Lipoprotein subclass profile | Results report an shift toward larger, more buoyant LDL and HDL particles without significant changes in quantitative total cholesterol amount. | Not Reported | | Poor
| | | | | | Excluded were those with chorinc systemic illness with or without secondary hyperlipidemia and current smoking. | | | Subsequently, following a 6 week washout period, the groups crossed over. | | Cross-over results presented in aggregate.
| | | | | | | | | | | LDL was higher for HAD+diet compared to placebo + diet (226+86 vs 216+92). LDL-1 and LDL-3 had signficant differences vs. placebo.
| | | | | | | | | | | HDL-2 was significantly higher for DHA+diet vs placebo +diet as compared to diet alone. No significant change in HDL overall, or in triglycerides.
Epstein, 1989 ^217^ | Diet and exercise combination | RCT | To assess the effects of weight change over 6 months on serum lipid changes | 6 months | Community | 1 Children ages 8–12; 2 One child and one natural parent who were >20% of ideal weight for age, sex and height.; 3 Child's triceps skinfolds >95th percentile for age and sex; 4 No history of psychiatric contact for the children | 56 children randomly assigned to diet (n=18), diet plus life-style exercise (n=19) or no treatment control (waiting list) (n=19). | mean age 10.5 in treatment groups, 10.3 in control | Diets were set between 3800–5000kJ/day and monitored by anutrtionis to maintain nutrient adequacy. | Weight, height, fitness, and serum lipids | Results for the two intervention groups (diet or diet+exercise instruction) were combined for total treatment group n=35 and control n=16. 51/56 completed the trial. 9 did not have 6 month serum data because they refused venipuncture. Values given as mean (SD) in mmol/L after 6 months: | NR other than 9 children refusing venipuncture. | | Poor
| | | | | | | | % overweight: 42 in treatment group, 50 in control group | Information on diet, exercise, stimulus control, reinforcement, modeling and contingency contracting was presented to parents and their children in eight weekly sessions followed by four monthly sessions. | | Change in total cholesterol was -0.27 (0.47) for intervention vs +0.09(0.50) for control, p=0.03
| | | | | | | | | | | Change in HDL was 0.20 (0.16) for intervention vs +0.06 (0.13) for control, p=0.007
| | | | | | | | | | | Change in triglycerides was -0.55 (0.53) for intervention vs -0.12 (0.30) for control, p=0.01
| | | | | | | | | | | Change in weight -3.6 kg (-17.4% change in percent overweight) for intervention vs +5.2 kg (-0.8% change in % overweight).
Ferguson, 1999 ^225^ | Exercise | Randomized cross-over trial of 4 months of exercise training (ET) | To examine the effect of exercise training on obese children | 8 weeks | Obese children living in community near the Medical College of Georgia; recruited via community fliers and community/hospital newspapers | Inclusion criteria: children need to have a triceps skinfold>85th percentile for gender, ethnicity and age and not be involved in any other weight control or exercise program, and not be restricted as to physical activity; all females were menarchal | 81 children; 2 were dropped for medical reasons prior to randomization. 79 children randomized. | Mean age, s.d= 9.5+1.0 yrs | 2 days diet recall | TC, HDL, LDL, TG, LDL-C size, Lp (a), ApoA-1, APoB, insulin, glucose, GHb(%), %fat and submaximal HR. | Results at months 4 (prior to cross-over) in mmol/L, least square mean+s.e. | NR | 76 children tested at month 4; 70 children tested at month 8. 3 subjects withdrew from the group that had no exercise in the first 4 months; 3 children withdrew from each group during the 2nd 4 month period. | Fair
| | | | | | | | mean height= 141.9+8.7 cm | Exercise program offered 5 days/week; children were paid $1/session for each day of attendance and given prizes for satisfactory participation (maintaining a HR>150 bpm). Transportation was provided to the program after school. | | TC: ET group (n=40) decreased from 4.29+0.08 to 4.04+0.08; control group (n=37) decreased from 4.63+0.08 to 4.27+0.08.
| | | | | | | | mean weight= 57.6+17.7 kg | Each session was 40 minutes long with 20 minutes of aerobic activity and 20 minutes of games that were designed to assure continuous activity. | | HDL: ET group (n=40) increased from 1.14+0.03 to 1.19+0.03 vs control group did not change (n=37) 1.35+0.03 to 1.35+0.03
| | | | | | | | black=44 subjects; white=37 subjects; Asian=1 subject | | | LDL: ET group (n=39) decreased 2.48+0.08 to 2.33+0.08 vs control group decreased 2.79+0.08 to 2.45+0.08
| | | | | | | | 26 boys and 53 girls | | | TG: ET group (n=39)decreased 1.15+0.01 to 0.95+0.01 vs control group (n=36) increased 0.98+0.01 to 1.10+0.01
| | | | | | | | | | | Lp (a): ET group (n=37)0.15+0.01 to 0.13+0.01 vs control group (n=37) decreased 0.16+0.01 to 0.12+0.01g/L
| | | | | | | | | | | Apo A-1: ET group (n=39) increased 1.10+0.03 to 1.24+0.04 vs control (n=37) decreased 1.31+0.03 to 1.28+0.03
| | | | | | | | | | | ApoB: ET group (n=39) decreased 0.77+0.01 to 0.76+0.02 vs control (n=37) decreased 0.79+0.01 to 0.74+0.02.
| | | | | | | | | | | Results significant for the change in TG ("p-0.02 for the group × time interaction over entire 8 months). Results also given for both groups at the end of the cross over period.
Gold, 1991 ^231^ | Diet | RCT | To evaluate serum apolipoprotein and lipid profile effects of an oat bran supplemented low-fat diet in children with elevated serum cholesterol. | 4 weeks | School-age children in the U.S. | 1 Cholesterol level over 185 mg/dL | 49 | Mean age: 10 years | Subjects given American Heart Association Step 1 Guidelines (fat intake limited to 30% of total calories and cholesterol to 300 mg/day), then randomized to control or oat bran supplemented (OBS) groups. OBS consumed an estimated 38 grams of oat bran/day in the form of cereals and snack bars for 4 weeks. | ApoA1, apoB, total cholesterol, LDL, HDL, and triglycerides | OBS had decreased apoB (-9mg/dL) vs control (2mg/dL), p=0.05. No significant differences between groups in total cholesterol, apoA, LDL, HDL, or serum triglycerides. | No adverse side effects or symptoms reported. | No information on compliance, withdrawals, intent-to-treat. Very brief write up. | Poor
Gylling, 1995 ^39^ | Diet | Randomized cross-over trial of diet | To assess the effect of sitosterol rapeseed margarine vs. rapeseed margarine without sitosterol | 6 weeks each arm | 14 children with HeFH Helsinki, Finland | Diagnosis of FH established in children and in one parent mostly by DNA technique | 14 children with HeFH and 1 child with HoFH (2 yr old) | 7 boys, 7 girls | Children were randomized to replace 24 grams of their normal daily fat intake by the same amount of a rapeseed oil-rich margarine with or without sitostanol ester (M vs MS). All children had previously been advised to use a low animal fat-low cholesterol diet rich in monoenic fatty acids for years. | TC, VLDL, IDL, LDL, HDL, HDL/LDL ratio, HDL2, HDL3, phospholipids and subfractions, triglycerides and subfractions. | Results combined after cross over, p-value assumed given notation of “significant change between groups.” mean+SE in mmol/L, pre values were combined. | Children noted no difference in taste between the two margarines. | | Poor
| | | | | | | | Mean age 9.1+1.1 yr (2–15) | Protocol results in daily consumption of 3 grams of free sitostanol in MS group. | | TC: decreased from 7.68+0.36 to 7.62+0.32 in M group vs 6.81+0.34 in MS group (10.6% lower in MS group, p<0.05). | Report “good compliance,” and “well tolerated.”
| | | | | | | | | | | LDL decreased from 5.64+0.35 to 5.47+0.30 in M group vs 4.65+0.32 in MS group (15% lower in MS group, p<0.05).
| | | | | | | | | | | VLDL increased from 0.21+0.05 to 0.26+0.06 in M group vs 0.25+0.07 in MS group (3.8% lower in MS group, NS).
| | | | | | | | | | | HDL increased from 1.17+0.07 to 1.20+0.07 in M group vs 1.25+0.08 in MS group (4.2% higher in MS group, NS).
| | | | | | | | | | | TG increased from 0.87+0.10 to 1.03+0.13 in M group, vs 0.92+0.12 in MS group, (10.7% lower in MS group, NS).
| | | | | | | | | | | Data reported separately for HoFH boy
Kang, 2002 ^226^ | Exercise | RCT of exercise. | To test whether high intensity physical training would have a favorable effect on components of the insulin resistance syndrome in obese adolescents | 8 months | Obese 13–16 year old youths were recruited. | Inclusion criteria: | 80 obese youths enrolled in two cohorts and randomized within gender and sex to one of three groups: lifestyle education alone (LSE); LSE+moderate intensity physical training (PT); and LSE + high intensity PT. | White boys: n=10, mean age 14.5years. | Physical training was offered 5 days/week for 8 moths except during the weeks that they were assigned to lifestyle education (LSE). | 1 TC, HDL, LDL, Lp (a), apo A1, ApoB, glucose, insulin, triacylglycerol; 2 Percentage of body fat; 3 Systolic and diastolic BP | Pre-post changes in mmol/L least-square mean+SEM: | Not Reported | | Poor
| | Atlanta, GA | | | | 1) triceps skin-fold greater than the 85th percentile for gender, ethnicity and age; 2) no involvement in any other weight control or exercise program; 3) no restriction with respect to ability to engage in physical activity. | | white girls: n=15, mean age 15.3yr. | Physical training program involved an individual exercise prescription based on baseline treadmill test, designed for 1045 kJ/session (250kcal) regardless of whether it was high/moderate intensity. | | TC: LSE alone increased 0.24±0.10 vs LSE+PT decreased 0.03±0.09, p=0.066.
| | | | | | | | black boys: n=16, mean age 14.1yr. | The intensities corresponded to a mean prescribed HR of 55–60% peak for moderate intensity group and 75–80% of peak for high intensity group. | | HDL: LSE alone decreased 0.03±0.04 vs Lse+PT decreased 0.03±0.04, p=0.958.
| | | | | | | | black girls: n=39, mean age 15.2 yr. | | | VLDL: LSE alone increased 0.12+0.04 vs LSE+PT decreased 0.04+0.04, p<0.001
| | | | | | | | | | | TG: LSE increased 0.12+0.08 vs LSE+PT decreased 0.22+0.08, p=0.002
| | | | | | | | | | | Lp (a): LSE increased 2.45+4.79 mg/dL vs LSE+PT increased 9.88+4.32, p=0.263
| | | | | | | | | | | Apo A1: LSE increased 10.51+4.31 vs LSE+PT increased 12.40+3.90, p=0.748
| | | | | | | | | | | ApoB: LSE decreased 1.03+3.29 vs LSE+PT decreased 0.30+2.97, p=0.868.
Knipscheer, 1996 ^71^ | Drug | double-blind, randomized placebo controlled study, children stratified by age. 4 arms (3 doses of pravastatin, 1 placebo) | To assess the safety, tolerability and efficacy of pravastatin for HeFH | 12 weeks, following an 8 week diet and placebo run-in period. | Lipid clinic | Children with “known heterozygous FH” were eligible. HeFH defined as plasma LDL above 95th percentile for age and sex during lipid-lowering diet AND hypercholesterolemia in siblings, parents or grandparents, or clinical manifestations of premature atherosclerosis prior to age 50 in 1st/2nd degree relatives. | 72 children with HeFH | 25 male; 47 female | Pravastatin 5, 10 and 20 mg/day | 1 TC, LDL, HDL, TG, Apo B100; 2 TSH, cortisol, ACTH before and after treatment period; 3 Physical exam at entry and final visit. | 1 Compliance was 93%; 2 At week 12: TC and LDL were significantly reduced in all pravastatin treated groups compared with baseline (p<0.05). LDL: 5 mg/day - 20% decrease; 10 mg/day - 20% decrease; 20 mg/day - 30% decrease (from baseline LDL levels of 247.49 mg/dL for P, 239.75 mg/dL for 5mg/day, 235.89 mg/dL for 10 mg/day and 259.01 mg/dL for 20 mg/day. | Total number adverse events P- 9, 5 mg/day - 3, 10 mg/day - 6, 20 mg/day - 1. | | Good
| | | | | The Netherlands | Exclusions:; 1 Major surgery within the past 3 months; 2 Use of medications interfering with lipid metabolism (anticonvulsants, oral contraceptives, corticosteroids, fibric acid derivatives or immunosuppressants).; 3 Hepatic or renal dysfunction | | 66/72 White; 5/72 Black. | | ALT, AST, T bilirubin, CK, Alk phos. | TC: 5 mg/day - 18% decrease; 10 mg/day - 18% decrease; 20 mg/day - 25% decrease (from baseline TC of 301.63 mg/dL for P, 297.76 mg/dL for 5 mg/d, 235.89 mg/dL for 10 mg/d, and 317.09 mg/dL for 20 mg/day. (all numbers estimated from graph). | List: rash, fatigue (P only), nose bleeding, headache, diarrhea (P only), dyspepsia (P only), nausea/vomiting, abdominal pain, myalgia (P only).
| | | | | | | | Mean age 11.9–12.1 across 4 groups. | | | Plasma LDL cholesterol levels were not reduced below the 95th percentile for sex and age, except for 2 children in the 20mg pravastatin group, and 1 child each in the 5 and 10 mg pravastatin groups. | Laboratory safety measurements did not show significant changes in any of the groups between the end of the treatment period and baseline. However CK abnormal in 8 of P, 6 of 5mg/day, 11 of 10 mg/day and 8 of 20 mg/day.
| | | | | | | | | | | Plasma HDL showed a mean increase of 11% (from baseline of 46.4 mg/dL) in the 20 mg pravastatin group (p<0.001), but was unchanged in the other groups. | Cortisol abnormal in 2 of P, 2 of 5 mg/d, 5 of 10 mg/d, 3 of 20 mg/d.
| | | | | | | | | | | TG did not change as compared from baseline in any group.
| | | | | | | | | | | Plasma VLDL and Apo B100 levels were reduced in all pravastatin treatment groups (p<0.05 and p<0.001 respectively).
Kuehl, 1993 ^227^ | Diet | RCT of parental and family education | To identify and characterize a family-based group intervention to lower plasma cholesterol in children. | | Children with TC ≥185 | Children referred by physicians who participated in a seminar on the risk factors for atherosclerosis in children, identification and management of high cholesterol in children. 14 pediatric practices referred 295 children. | 295 children randomized to either a single session intervention (SSI) or a multi-session intervention (MSI) | SSI group: mean age 6.6 | 1 SSI=one 90 minute nutrition education session for patient, siblings and parents (slides presentation, low fat food prep and tasting, distribution of fruit and cereal). “Returned for subsequent food sampling with nutritionist present” but no further formal education.; 2 MSI= four 90 minute sessions with focus on food preparation for breakfast, snack, lunch and dinner. Received notebooks with nutrition information and recipes, incentives for attendance and completion of behavioral contracts (eating low fat meal) | 1 TC, TG, LDL, HDL; 2 Caloric intake; 3 Diet composition; 4 Nutritional intake of calcium and iron; 5 Growth | Both groups had improvement in TC from baseline to the second visit: | Both groups maintained iron intake at over 87% and calcium intake at over 81% of the RDA throughout the study. % RDA of iron reported baseline to visit 2: MSI 103±5 to 98±5 (pNS); SSI 87± 4 to 90±4 (p=NS). | Large and unequal drop out rates (35% for SSI and 16% for MSI) and analysis only use those who completed the second blood draw (215 of original 295); ie not intention to treat. | Poor
| | USA | | | ages 2–15 (mean 7) | | | gender: NR | | | TC: MSI group TC (n=90) decreased from 207.9±3.2 to193±3.0 (p<0.0001; SSI group (n=87) TC decreased from 206.1±3.3 to 198.5±3.3 (p<0.01). | All patients "grew linearly with a mean height increase of 2.0±0.3 inches in the MSI group and 2.0±0.1 in the SSI group. Both groups had a mean weight increase of 4.1 lbs. Growth parameters not significantly different between the two groups. | No assessment of intervention fidelity.
| | | | | | | | race: NR | | | HDL: MSI group decreased 53.7±1.4 to 51.6±1.4 (p<0.08). SSI group NR. | | 18% of MSI and 20% of SSI had plasma TC values <170 and were excluded from the analyses because they didn't meet the initial referral criteria of TC ≥ 185.
| | | | | | | | MSI group: mean age 7.6 | | | LDL: MSI group decreased 137.0±3.6 to 124.9±3.3 (p<0.0001); SSI group NR.
| | | | | | | | gender NR | | | TG: MSI group decreased from 88.5±6.8 to 83.5±5.1 (p NS); SSI group NR.
| | | | | | | | race NR | | | Both groups had a significant decreased in the proportion of total calories obtained from fat.
| | | | | | | | | | | Both groups had a significant increase in the proportion of total calories obtained from protein.
| | | | | | | | | | | Total calorie intake decreased in the MSI group but not in the SSI group: MSI 1464±34 to 1348±31 (p<0.002); SSI group 1358±33 to 1306±32 (p=NS).
Lambert, 1996 ^72^ | Drug | RCT of drug multicenter: 6 sites in Canada | To determine the efficacy, safety and tolerance of short-term administration of lovastatin in a male pediatric population with severe FH, and to evaluate dose-response relationship. | 8 weeks of randomization to meds vs. placebo; 4 wk run-in for both groups. | Boys aged 17 or younger with heterozygous FH | 1 Weight 27 kg or more; 2 Plasma LDL above 95th percentile for age while on lipid-lowering diet; 3 History of unsuccessful treatment with bile acid-binding resins; 4 Family history of atherosclerosis at or before age 50; 5 Documented family history of hyperlipidemia with LDL > 95th percentile for age and sex before treatment or a personal diagnosis of FH substantiated by LDL receptor activity or mutation.; 6 No significant concomitant conditions; 7 Weight and height not 3 – 97th percentile for age | 69 randomized, | 10 mg/day group | After pre-study visit and lab tests, all lipid-lowering medications were discontinued at least 8 weeks before study start, with no lipid-lowering therapy allowed other than that permitted by study protocol. Placebo given weeks -4 to 0, followed by randomization to double-blinded active treatment of lovastatin at 10, 20, 30 or 40 mg/day for 8 weeks. Medication dispensed at weeks -4, 0, and 4. | Total cholesterol LDL Apolipoprotein B Safety Compliance | All doses reduced total cholesterol, LDC, and ApoB (P ≤ .0001 for all). Mean percent change from placebo to end of treatment varied from -17% to -29% for total cholesterol values, from -21% to -36% for LDL, and from -19% to -28% for ApoB. Dose response relationship, with improved results up to a dose of 30 mg/day. | No serious clinical adverse effects reported | No separate control group: patients served as own controls | Fair
| | | | | | | 17 to 10 mg/day group | Mean age: 12.5 (2.4) | Compliance verified by tablet count at weeks 0, 4 and 8. Clinic follow-up visits at weeks -4, -2, 0, 2, 4, 6, and 8. | | Drug well-tolerated. Increased aspartate aminotransferase concentrations, with no evidence of a dose-response relationship, and no value exceeding 2× the upper limit of normal. No change in alanine aminotransferase. Three patients had ≥ asymptomatic elevations in creatine kinase, which spontaneously returned to normal, with no action required regarding the drug.
| | | | | | | 18 to 20 mg/day group | Female gender: 0 | Complete physical exam at weeks 0 and 8. Ophthalmologic exam during placebo period and within 8 weeks of study exit. Patients continuously counseled by dietician to follow lipid-lowering diet throughout the trial. Daily food records completed by patients for 3 consecutive days and reviewed by a dietician at weeks -4, 0, 4, and 8. | | 85% of patients took at least 70% of the prescribed dose during the active treatment period.
| | | | | | | 19 to 30 mg/day group | Race: 94.1% white
| | | | | | | 15 to 40 mg/day group | 20 mg/day group
| | | | | | | | Mean age: 12.7 (1.6)
| | | | | | | | Female gender: 0
| | | | | | | | Race: 100% white
| | | | | | | | 30 mg/day group
| | | | | | | | Mean age: 13.3 (2.7)
| | | | | | | | Female gender: 0
| | | | | | | | Race: 94.7% white
| | | | | | | | 40 mg/day group
| | | | | | | | Mean age: 12.9 (2.7)
| | | | | | | | Female gender: 0
| | | | | | | | Race: 93.3% white
Linder, 1983 ^232^ | Exercise | RCT | To determine the effect of an 8-week physical conditioning program on the serum lipid and lipoprotein levels in healthy white male adolescents. | 8 weeks | Volunteers from middle income families, all subjects were members of Boy Scout troops. Any boys with health problems and those taking medication were excluded. | | 50 healthy boys randomly assigned to either control (n=21) or physical conditioning (n=29). | boys ages 11–17; all white | Subjects in the physical conditioning group were required to participate in 4 days/week of exercise. This program consisted of 3 days of an alternating walk-jog program (60 seconds each) and 1 day of competitive team soccer or rugby (min 1 hour). Jogging segments were run at a rate that increased the subject's pulse rate to 80% of the maximum pulse rate reached during individual working capacity testing at baseline. | 1 48 hour dietary history kept by parents and subjects; 2 Height, weight, triceps skin fold, resting pulse rate, blood pressure, relative body weight calculated using Weight-for-Length Index. | 1 Physical working capacity increased in the PA group from pre to post (16.2+3.4 to 18.7+3.5 kpm/min/kg) as compared to the control group (16.4+3.3 to 16.3+2.9 kpm/min/kg). p<0.05 for the difference between the PA and control groups post-test results.; 2 No significant differences were noted in weight, height, skinfold, BP or resting pulse rate, dietary components; 3 There were no significant differences in the change in serum cholesterol levels from pre to post or between groups. | NR | No sessions were missed due to illness; any sessions missed for vacation were completed under parental supervision; 1 day per week was offered as a make-up day. | Fair
| | Augusta, GA | | | | | | | Subjects in the control group participated in their usual summer activities. | | Total cholesterol: PA group 148.14+22.39 pre to 147.23+26.49 post vs control group 149.45+24.87 pre to 148.22+29.34 post mg/dl | | 39 of 50 subjects completed the post-tests; 8 of the 29 subjects in the physical conditioning group were excluded because they failed to fulfill adequately all the requirements of the exercise program. 3 of the 21 subjects in the control group failed to return for follow up testing and were not included in the final analysis.
| | | | | | | | | | | LDL: PA group 93.90+20.93 to 97.25+22.86 vs control group 95.20+23.36 to 101.00+33.44 mg/dL
| | | | | | | | | | | HDL: PA group 41.33+8.39 to 37.38+7.87 vs. control group 40.20+8.39 vs 37.94+8.59
| | | | | | | | | | | VLDL: PA group 15.38+8.15 to 14.47+8.28 vs control group 14.55+10.77 vs 13.89+10.68
| | | | | | | | | | | Triglycerides: PA group 84.14+29.47 to 84.00+25.40 vs control group 81.70+28.71 vs 87.17+34.12
Malloy, 1978 ^73^ | Drug | Single-blind random assignment pattern with cross-over at 6 months - drug | To determine the effect of p -aminosalicylic (PAS) on serum cholesterol and triglycerides in 3 lipoprotein classes in children and adolescents with severe familial hypercholesterolemia. | 6 months each condition (drug and placebo); follow-up at 12, 18, and 24 months for some. 4 month run-in period for all prior to randomization. | Children aged 5 to 21 years with severe familial hypercholesterolemia; asting triglycerides were normal and electrophoresis of serum in agarose gel showed a predominant narrow liporptien band of beta moility in all patients. | 1 Severe familial hypercholesterolemia; 2 Consistently elevated serum cholesterol while on ≥ 4 month diet restricted in cholesterol and saturated fats; 3 No disorders known to contribute to secondary hyperlipidemia; 4 No other serious disorder; 5 No medications other than PAS; 6 One parent with proven and one other in kindred with hypercholesterolemia. | 20 enrolled | Median age: 12 years | Dietary cholesterol and saturated fats restricted 4 months prior to and throughout the study. Subjects and their parents received monthly dietary counseling. Single-blind assignment to active drug (150 mg/kg/day, up to 8 gm/day) or placebo during first 6 months. Dose adjusted monthly for change in body weight. After 6 months, the alternate agent (placebo or active drug) was given for 6 months. | 1 Serum cholesterol; 2 Triglycerides; 3 LDL; 4 HDL; 5 TSH | 1 Mean serum cholesterol levels for all subjects were 14% lower during the 6 months of treatment with diet and PAS-C vs diet alone (p<.001). Those in the compliant subgroup decreased 19.5% below control levels with PAS-C (p<.001); 2 Mean fasting serum triglyceride levels of all patients were within the normal range with diet alone, and decreased 15.7% when PAS-C was added (p<.001). Levels in the compliant subgroup were not lower than those of other patients, suggesting a smaller dose of PAS-C may be maximally effective.; 3 In paired samples of serum from 8 subjects, LDL decreased in all and the mean content of serum cholesterol in the LDL fraction declined 24% below control levels during treatment with drug (p<.002).; 4 No difference in HDL with drug; 5 No difference in TSH with drug | No indicators of drug toxicity reported, other than mild gastric irritation that remitted with oral antacid treatment. | Single-blind randomization | Poor
| | USA | | | | | | Female gender: 45% | Composite index of compliance for each subject based on interviews, tacit drug inventories, and tests for PAS metabolites. Monthly clinic visits including clinical exam. | | | | No separate control group: patients served as own controls
| | | | | | | | | | | | | Only 11/20 subjects were > 50% compliant
| | | | | | | | | | | | | LDL change evaluated for 8 subjects only
McCrindle, 1997 ^74^ | Drug | Randomized crossover patients recruited from 2 lipid disorder clinics | To compare acceptability, compliance and effectiveness of two forms of cholestyramine resin in treatment of hypercholesterolemia in children. | 28 weeks | 2 pediatric lipid clinics; children with familial hypercholesterolemia | 1 Age 10 – 18 years; 2 1 or more parent with heterozygous familial hypercholesterolemia type IIA or IIB; 3 Fasting serum LDL of 130 mg/dl or more while on American Heart Association step 2 diet; 3 No contraindications to use of cholestyramine; 4 No lipid-lowering agents other than those in study protocol | 40 | 43% female | 6 week washout period followed by random assignment in pairs to either 8 grams/day of cholestyramine powder (4 gram packets) or pills (1 gram tablets) for an 8 week period. Drug dispensed with random over count, and subjects instructed to return unused drug at end of drug period. Subject completed log book during the 1st week on amount of drug taken, acceptability and adverse effects, with questionnaire at weeks 4 and 8. After the first 8 week course of medication and assessment, there was another 6 week wash-out, followed by crossover to the alternate form of medication and assessment. | Baseline assessment: self-administered questionnaire on attitudes, health beliefs and perceptions re: hypercholesterolemia, detailed medical and family history, food frequency questionnaire. | Reduction in LDL for both pills (-10% +/- 20%, p=0.006) and powder (-15% +/- 17%, p=0.0001) with no significant difference between forms (p=0.16). | 38/40 (95%) completed both medication periods | No control group | Fair*
| | | | | | | | 2 siblings from 6 families | | Fasting lipid profile | At end of study, 82% preferred pill, 16% powder, and 2% neither form. Mean (+/-SD) compliance as assessed by amount of medication taken was greater for pills (61% +/-31% than powder (50% +/- 30%, p=0.01). Form of medication increased compliance by at least 25% for 16 patients (42%), 13 in favor of pills and 3 of powder. | Authors noted minor gastrointestinal complaints were frequent but did not result in any drop-out | Small sample size
| | | | | | | | 3 siblings from 1 family | | Complete blood cell count | Compliance not associated with patient attitudes or perceptions of hypercholesterolemia, demographics, family history, previous experience with lipid-lowering medications or lipid-profile parameters. | | At baseline, pill group had perception of increased importance of diet
| | | | | | | | Median age at enrollment: 13 (10–18) | | Serum chemistry determinations
| | | | | | | | Median age at diagnosis: 9.5 (0.1–17.2) | | Physical exam
| | | | | | | | | | Dietary assessment
| | | | | | | | | | Questionnaire on ease of drug use and compliance
McCrindle, 1998 ^235^ | Diet | Randomized trial | To determine compliance, safety, and efficacy of therapy with garlic extract in lowering cholesterol levels in children and adolescents with hypercholesterolemia | 8 weeks | Lipid clinic, Toronto, Canada | Children between ages 8–18 | 30 randomized to either garlic supplement or identical placebo | 16 males, 14 females | 1 whole 300 mg tablet of garlic extract (Kwai, Lichtwer Pharma, Berlin, Germany) containing 0.6 mg of allicin placed in a gelatin capsule with inert filler. One bulb of Chinese-grown garlic provides the same amount of allicin as that provided by 6 tablets of garlic extract. | Compliance | Relative to placebo, garlic treatment resulted in: | At the end of study, 13% of placebo group and 21% of garlic group reported adverse effect (p=0.66), the most common being headache. Upset stomach was also reported by both groups at the mid-oint questionnaire. No effects on hight, wieght or blood pressure. Serum albumin level and hemoglobin levels increased in the garlic treated group (p=0.002 for albumin and p=0.02 for hemoglobin) | | Fair
| | | | | | Positive family history of hypercholesterolemia or prematrues atherosclerotic cardiovascular disease in first-degree relative | | Mean age 14.0±2.3 years | Placebo consisted of identical gelatin capsule with inert filler only. | Fasting TC, LDL-C, HDL-C, TG, and Apo A-1, Apo B-100 | TC increase 0.6 mmol/L (p=0.86) | Compliance 78±22% of expected for placebo and 72±21% for garlic group.
| | | | | | Minimum fasting TC >185 mg/dL | | | | | LDL-C deccrease 0.5mmol/L, p=0.90
| | | | | | Participating in a dietary counseling program | | | | | HDL increase 9.3 mmol/L, p=0.29
| | | | | | Compliance with NCEP Step II diet for at least 6 months | | | | | TG decrease 0.72 mmol/L, p=0.70
| | | | | | Excluded: secondary dyslipidemias, hisotry of major surgery or illness within 3 months of enrollment
McCrindle, 2002 ^75^ | Drug | Randomized cross-over trial | To determine the short-term safety and effectiveness of combination drug therapy in children | 18 weeks each period | Lipid clinic, Toronto, Canada | 1 Children between ages 8–18; 2 Positive family history of hypercholesterolemia or premature atherosclerotic cardiovascular disease in first-degree relatives; 3 Minimum fasting LDL cholesterol level before enrollment > 160.5 mg/dL; 4 Participation and compliance in dietary counseling program for at least 6 months.; 5 No secondary cause for hyperlipidemia, no major surgery or serious illness within past 3 months. | 40 randomized to either colestipol 10grams/day alone or colestipol 5 grams/day +pravastatin 10 mg/day | 11 girls, 25 boys | colestipol 10grams/day (10 tablets) alone vs colestipol 5 grams/day (5 tablets) plus pravastatin 10 mg/day (1 tablet) for first 18 week period, followed by 8 week wash-out period and then each group crossed over to the other treatment for the second 18 week period. | Acceptability Compliance LDL, total cholesterol, Apo-B 100, triglycerides | No data reported prior to cross-over. | Symptoms reported at the end of the study in the final preference questionnaire showed that the majority of patients had no symptoms. 18% reported constipation with colestipol vs 0% with the combination vs 3% who had it with both, 12% reported bloating/gas with colestipol alone vs 0% with combination (3% had it with both). 21% had stomach ache with colestipol alone vs 0% with combination vs 0% with both. 11% had headache with colestipol vs 0% with combination vs. 3% with both regimens. 6% had muscle aches on colestipol along vs 3% with combination vs 0% with both regimens. | | Poor
| | | | | | | | median age 14, range 9–18 | | | Results as mean change +SD in mg/dL
| | | | | | | | BMI 22–25 kg/m2 | | | Total cholesterol: -0.63+0.80 for C vs -1.06+1.10 for C+P, p=0.041
| | | | | | | | | | | LDL: -0.65+.80 for C vs -1.07+1.06 for C+P, p=0.066
| | | | | | | | | | | HDL: +0.01+0.18 for colestipol vs +0.03+0.13 for C+P, p=0.63
| | | | | | | | | | | Triglycerides +0.11+0.68 for colestipol vs -0.07+0.72 for C+P, p=0.28
| | | | | | | | | | | Apo A-1 (g/L) +0.06+0.16 for C vs +0.07+0.13, p=0.81
| | | | | | | | | | | Apo B-100 (g/L): -0.19+0.24 for C vs -0.26+0.31 for C+P, p=0.48
McCrindle, 2003 ^76^ | Drug | RCT of drug | To determine the safety and efficacy of atorvastatin (10 to 20 mg) in children and adolescents with familial hypercholesterolemia (FH) or severe hypercholesterolemia | 26 weeks of treatment or placebo, then all subjects recieved 26 weeks of treatment | Children aged 10 to 17 with FH or severe hypercholesterolemia | 1 Known FH or severe hypercholesterolemia and LDL-C≥190mg/dL or LDL-C ≥ 160 mg/dL and a family history of FH or documented premature CV disease in a 1st or 2nd degree relative;; 2 TG ≤ 400 mg/dL;; 3 ≥ Tanner stage II;; 4 Not premenarche, pregnant or breastfeeding;; 5 Testicular volume > 3cm^3^ after age 12;; 6 Weight between 10th and 95th percentile for age;; 7 No liver or kidney disease;; 8 No known sensitivity to statins | 187 randomized, | Atorvastatin group | After a 4 week baseline/placebo phase in which subjects were instructed to follow the NCEP step 1 diet, those whose LDL-C remained ≥ 160 mg/dL and had TG ≤ 400 mg/dL at week -2 were randomly assigned in 3:1 ratio to receive 26 weeks double blind treatment with drug (10mg/d) or placebo. Drug could be titrated to 20 mg/d at week 4 for those not at LDL-C ≤ 130 mg/dL. Those completing double-blind were eligible to continue treatment for 26 weeks with open label atorvastatin (10 mg/d). | 1 Change in LDL-C, total cholesterol, triglycerides, HDL, and apolipoprotein B from baseline to week 26; 2 Safety as measured through week 52 by standard blood measurements, safety laboratories, blood pressure, pulse and physical examination | 1 LDL-C reduced compared to placebo (-40% vs -0.4%, p<.001). At week 26, change in total cholesterol greater in drug group than in placebo (-32% vs -1.5%; p<.001), as well as changes in triglycerides (-12% vs + 1.0%; p=0.03) and apolipoprotein B (-34% vs +0.7%; p<.001).; HDL cholesterol decreased with drug vs placebo (+2.8% vs -1.8%; p=.02).; 2 Drug tolerated as well as placebo. Incidence of treatment-related adverse events during double-blind: 7% in drug vs. 4% in placebo group (p=.7) Most adverse effects were mild or moderate. Drug had no effect on sexual development. | No significant adverse effects documented | | Good
| | 20 centers world-wide (US, Canada, Europe, South Africa); open label. | | | | | 140 to drug | Mean age: 14.1 (2.0)
| | | | | | | 47 to placebo | Female gender: 32%
| | | | | | | | Race: W: 94%
| | | | | | | | B: 1.4%
| | | | | | | | A: 1.4%
| | | | | | | | Placebo group
| | | | | | | | Mean age: 14.1 (2.2)
| | | | | | | | Female gender: 28%
| | | | | | | | Race: W: 87%
| | | | | | | | B: 2.4%
| | | | | | | | A: 2.4%
Obarzanek, 2001 ^218^ | Diet | RCT | To evaluate the long-term safety and efficacy of a cholesterol-lowering diet in children with elevated LDL | 4 years; treatment changed at 6 months, 12 months, and at 2 and 3 years. | Prepubertal girls aged 7.8 – 10.1 years and boys aged 8.6 – 10.8 years were recruited from schools, an HMO, and pediatric practices. | 1 Average of 2 LDL-C values in 80th – 98th sex-specific percentiles for 8 – 10 year old children in a fasting state; 2 No medical conditions or medications that could effect growth or serum cholesterol, behavioral problems or onset of pubertal maturation. | 663 randomized, | Intervention group | Randomized to dietary intervention or control group. | 1 Dietary intake; 2 Serum LDL-C, height, serum ferritin; 3 Serum total cholesterol, HDL-C, LDL-C/HDL-C, triglycerides, red blood cell folate, serum retinol and zinc, sexual maturation | 1 Reductions in dietary total fat, saturated fat were greater in intervention than in control throughout the intervention period (p<.001). Differences in dietary cholesterol intake between intervention and usual care groups were significant at 1, 3, and 5 years (all p<.001), but not at the last visit. At 1 and 3 years energy intake was lower in intervention vs control (p=.01 and p<.0001, respectively); 2 At 1, 3, and 7 years follow-up, intervention had 4.8 mg/dL, 3.3 mg/dL, and 2.0 mg/dL lower LDL-C than control, respectively. Mean adjusted differences between the 2 groups were significant at 1 and 3 years (p<.001 and p<.02, respectively), but not at 5 years (p=.11) or the last visit (p=.25). No significant differences in height or serum ferritin.; 3 Total serum cholesterol lower in intervention than usual care at 1 (p<.001) and 3 years (p=.04), but not at 5 or 7 years. HDL-C was higher in control than intervention at 1 year (p=.03), with no difference at years 3, 5 or 7. | No differences at any data collection point in height or serum ferritin or any differences in an adverse direction in red blood cell folate, serum retinol and zinc, sexual maturation or body mass index. | Higher proportion of intervention vs control had household income < $20,000 (15.1% vs. 5.9%; p=.002). Secondary analyses suggests this may have effected results. | Good
| | 6 clinical centers in the USA | | | | | 334 to intervention | Mean age: 9.5 (.74) | Intervention: Dietary behavioral intervention that promoted adherence to a diet with 28% of energy from total fat,< 8% from saturated fat, up to 9% from polyunsaturated fat, and <75 mg/1000 kcal cholesterol per day. | | No differences seen in LDL-C/HDL-C or triglycerides. | | 87.5% participated in final follow-up
| | | | | | | 329 to control | Female gender: 46% | Control: Usual care - parents informed child's blood cholesterol high and were given educational materials on heart-healthy eating as available to the public. | | Serum retinol was higher in the intervention group at 3 (p=.04) and 7(p=.02) years. There were no other differences between the groups in nutritional biochemical measures. There were no differences in weight or measures of sexual maturation, or in intake of recommended vitamins and minerals. | | Only 1.3 of 4 scheduled intervention visits per subject were achieved in the final year.
| | | | | | | | Race: 86.5% of entire study sample white | Annual examinations for study-wide measurements. | | | | Intention to treat analysis conducted
| | | | | | | | Control group | Intervention: 1st six months: 6 weekly and then 5 biweekly group sessions led by nutritionists and behaviorists, and 2 individual sessions with nutritionist. 2nd six months: 4 group and 2 individual sessions. 2nd and 3rd years: group and individual maintenance sessions held 4 – 6 ×/year, with monthly phone contacts between group sessions. 4th year: individualized approach with motivational interviewing and stage of change. 2 group events and 2 individual visits annually, with individual phone contacts “as appropriate”. | | | | Dietary intake based on self-report and may be biased.
| | | | | | | | Mean age: 9.5 (.70)
| | | | | | | | Female gender: 44%
| | | | | | | | Race: 86.5% of entire study sample white
Savage, 1986 ^233^ | Exercise | RCT | To compare the serum lipid and lipoprotein response to identical exercise training in young children and adults. | 11 weeks | Subjects recruited by media from Omaha, Nebraska metropolitan area | Inclusion criteria:; 1 Prepubescent boys (no pubic hair as confirmed by parents) or adult males ages 30–45.; 2 No regular (≥3×/week) aerobic exercise program within the last 3 months.; 3 No medical contraindications; 4 Medical examination and clearance by a physician within the last year.; 5 Non-smoker. | Subjects were randomly divided in to high, low and control groups (n=8 for Low, n=12 for High, n=10 for control). | Ages for boys not listed, all prepubescent | Training consisted of walking/jogging/running 3 times/week for 11 week for a total distance of 1.6 km per session. Participants had a 1 week period of accommodation preceding the training period. Low intensity group had a training HR of 40% VO2 max. High intensity training group had a training HR of 75% VO2 max. Control subjects were requested to maintain their current activity pattern throughout the study. | 1 Serum lipids; 2 Cardiorespiratory fitness (modified Bruce ETT), VO2 max.; 3 Body composition: weight, height, skinfold thickness, body density; 4 Dietary intake for 3 days. | For boys only: results as pre-post for low (L), high (H) treatment groups and control (C) mean+sd. | NR | | Fair
| | Omaha, Nebraska | | | | | | | | | HDL/cholesterol (%): Low group decreased 36+3.9 to 28+2.8; High group decreased 40+1.4 to 32+2.0; Control group 32+2.0 to 32+2.3. NS
| | | | | | | | | | | Triglycerides (mg/dL): Low group increased 50+2.1 to 55+3.5; High group increased 53+3.6 to 69+8.6; Control group increased 68+8.1 to 81+5.8. NS
| | | | | | | | | | | LDL (mg/dL): Low group increased 109+20.0 to 123+23.2; High group increased 88+3.8 to 92+3.6; Control group decreased 96+7.8 to 93+8.8. NS
| | | | | | | | | | | All post values were the average of two measurements taken on day 1 and day 2 post-completion of the training regimen. No significantly differences at p=0.05 by ANCOVA.
Shannon, 1994 ^220^ | Diet | RCT | To assess effects of a home-based, parent-child autotutorial (PCAT) dietary education program on the dietary knowledge, lipid consumption, and plasma LDL of 4 to 10 year old children with elevated plasma LDL-C. | 3 month follow-up | Children aged 4 –10 with elevated plasma LDL-C identified through a cholesterol screening program open to those served in 9 pediatric practices in suburban Philadelphia. | 1 Age 3.9 – 9.9 years; 2 85% to 130% ideal body weight for height; 3 No history of disease that would explain hypercholesterolemia; 4 No medications that would affect blood lipids; 5 Boys: mean fasting plasma LDL-C 107 – 164 mg/dL. Girls: 112 – 164 mg/dL. | 342 | Average age: 6.3 | Randomization into(1) Parent-child autotutorial program (PCAT) (n=88), (2) individual dietary counseling (n=86) or (3) at-risk-control groups (n=87) using permuted blocks within strata design with an adaptive allocation procedure to balance 1st order interactions with season and pediatric practice. | Dietary knowledge | Dietary knowledge scores: increased 3× more in PCAT vs counseling or at-risk control (p<.001). Lipid intake: Mean grams of total and saturated fat decreased in PCAT and counseling and increased slightly in at-risk control (p<.05). At-risk control knowledge and diet did not differ from that of not-at-risk group. Mean LDL-C decline of PCAT (10.1mg/dL) was greater than in at-risk control (4.1 mg/dL) (p<.05). This represents an 8% decline in the PCAT group. | Not Reported | At baseline, mean calorie intake of at-risk control group greater than in other groups (p<.05). | Good
| | | | | USA | Not at risk control group: 1 through 4, and TC at screening test below 60th percentile | | Girls: 50% | Adjustment made to select a comparable control group among children “not at risk” (n=81). | Lipid intake
| | | | | | | | Boys: 50% | After initial assessment, PCAT treatment included 10 talking book lessons and follow-up paper and pencil games for children with a manual for parents. Counseling treatment: 45–60 minute session with parent, child and registered dietitian, along with take home print materials for both. Dietitian available for phone to answer questions during 3 month period. | Plasma LDL-C level
| | | | | | | | White: 76.8% | | Weight and height
| | | | | | | | African-American: 6.75%
| | | | | | | | Other: 2%
Stallings, 1993 ^77^ | Diet | Randomized pilot study | To determine the effectiveness of a home-based dietary education program vs usual care in LDL, gain in knowledge of heart-healthy eating, and change in consumption of dietary fat | 6 months. PCAT is a 10-week lesson program; families got that and nothing else for 6 months. | Healthy children aged 4 to 10 with high LDL cholesterol referred to a research center. | 1 Plasma LDL between 90th – 99th percentile | 44 randomized, 20 to PCAT | PCAT group | After assessment and instruction to parents on use of measurements, randomized to PCAT or Usual Care. PCAT: 10 lessons, 1 per week completed in home by child and parents. Registered pediatric dietitian explained use of the program for self-education. | 1 Change from baseline in LDL cholesterol response; 2 Gain in knowledge of heart healthy eating patterns; 3 Change in consumption patterns of dietary fats | 1 No differences between groups at each time period; within both groups 3 and 6 month values were different from baseline (p<.01). Both groups maintained a decrease of about 10% over 6 months.; 2 Knowledge scores of the 2 groups did not differ during the study. Both groups had increases in knowledge at 3 and 6 months compared to baseline (p< 0.001).; 3 Calories: No difference between or within groups at each time period. | Not Reported | 86% completed 3 month follow-up. | Poor
| | USA | | Usual care families got 1 visit with a dietician and nothing else for 6 monhts. | | | 24 to usual care | Mean age: 8.3 (2.5) | Usual care: 1 hour session with registered pediatric dietitian who provided standardized guidance using an American Heart Association booklet. | | Total fat: No difference between groups at each time period. Within both groups, 6 month values different from baseline (p<0.05). | | 68% completed 6 month follow-up.
| | | | Assessments (serum and diet) at 3 and 6 months. | | | | Female gender: 40% | Assessment at 3 and 6 months | | Saturated fat: No difference between or within groups at each time period. | | Drop -out in specific variable data-sets was higher - EG: 66% completed knowledge test at 6 months.
| | | | | | | | Race: NR | | | Cholesterol: At 6 months, PCAT lower than Usual Care (p<0.05). Within both groups, 3 month values lower than baseline (p<0.05). At 6 month follow-up, Usual Care higher than at baseline (160 vs 89). | | High drop-out rate with resulting small N's in many comparisons. Dietary data based on self-report.
| | | | | | | | Placebo group
| | | | | | | | Mean age: 7.7 (2.2)
| | | | | | | | Female gender: 42%
| | | | | | | | Race: NR
Stein, 1999 ^78^ | Drug | RCT of drug | To assess the lipid-lowering efficacy, biochemical safety, and effect on growth and sexual development of lovastatin in adolescent boys with HeFH | 48 weeks | Boys aged 10 – 17 years with HeFH recruited from 14 pediatric outpatient clinics | 1 Followed American Heart Association (AHA) pediatric diet for at least 4 months; 2 LDL-C 189 mg/dL – 503 mg/dL; 3 At least 1 parent had an LDL-C of at least 189 mg/dL not due to secondary causes or LDL-C values were 220 – 503 mg/dL or their LDL-C values were 220 – 503 mg/dL and a parent died of CAD with no available lipid values.; 4 No homozygous FH, underlying disorders known to produce secondary LDL-C elevations; 5 No disorders affecting triglyceride-rich lipoproteins; 6 After the trial began, FDA requested only subjects who had Tanner stage 2 at entry be included in the trial.; 7 No delayed puberty shown by testicular volume ≤ 3 cm after age 12; 8 Weight ≥ 32 kg and between 10th – 95th percentile for age | 132 randomized, | Lovastatin group | All received formal dietary reinstruction, were monitored, and determined to be stable following a AHA pediatric diet for at least 8 weeks before randomization. | 1 LDL-C; 2 Growth; 3 Sexual development; 4 Biochemical, nutritional and endocrine parameters | 1 Lovastatin: reductions in LDL-C and total cholesterol at all dosages (p<.001 vs placebo) and in apoB at 40 mg/day. About 6% additional LDL-C lowering occurred with each doubling of lovastatin dosage. No significant changes in HDL-C or triglycerides compared to placebo. No changes in either group in Lp (a). During weeks 24–48, lovastatin reduced LDL-C and apo B 25% and 22%, respectively. No significant changes in other lipids or apoliproteins.; 2 Drug had no significant effect on growth parameters at 24 or 48 weeks; 3 No difference between drug and placebo in testicular volume, Tanner staging, testosterone, or LH level. DHEAS increased 18% in the drug group compared to 5% in the placebo group. (p=.03); 4 Reduction of tocopherol in drug group at week 48 (p=.002), consistent with decrease in LDL-C. In both groups, increase in ALT from baseline, with no differences between groups at week 48 (p=.20), although increase was significant for each group (drug, P<.001; placebo, P=.008). No consistent changes in AST or CK. Report of infrequent, sporadic, nonsustained CK elevations in response to exercise. | 1 drug and 2 placebo subjects discontinued due to adverse effects. No clinically significant adverse effects. | | Good
| | 14 pediatric clinics in the USA and Finland | | | | | 67 to drug | Mean age: 13.3 (0.3) | Placebo was administered week -4 to week 0. All subjects continued diet instruction, monitoring, and evaluation throughout the study.
| | | | | | | 65 placebo | Female gender: 0% | Randomized to drug: Lovastatin, starting at 10 mg/day, with a forced titration at 8 and 16 weeks to 20 and 40 mg/day, respectively. 40 mg/day weeks 25 – 48.
| | | | | | | | Race: 93% of all were white | Randomized to placebo: Matching placebo tablets
| | | | | | | | Placebo group
| | | | | | | | Mean age: 13.1 (0.3)
| | | | | | | | Female gender: 0%
| | | | | | | | Race: 93% of all were white
Stergioulas, 1998 ^228^ | Exercise | RCT | To investigate how physical exercise on a bicycle ergometer influences serum high-density lipoprotein cholesterol and prostacyclin levels | 2 months | Sedentary high school boys aged 10 – 14 years recruited from the random population study sample examined in the survey of the Greek Secretariat of Sports in 1993. | 1 Resident of Peania; 2 Lipids and prostanoids between normal concentrations (Szamosi et al); 3 Body weight between normal values (8 –10 kg lower the height) | 58 randomized, | Exercise group | 4 month lead-in phase. Randomized to exercise intervention or control. | 1 Physical work capacity; 2 HDL-C; 3 6-keto-PGF1a concentration | 1 Physical work capacity of exercise group increased at the end of treatment (p<0.001). No change seen in control group.; 2 Exercise group had higher HDL-C at end of the 2nd treatment month (p<0.005) and at the end of the detraining period (p<0.01). No change seen in control group.; 3 Exercise group had higher 6-keto-PGF1a concentration at end of 2nd treatment month compared to baseline (p<0.001) and lower 6-keto-PGF1a concentration at end of the detraining period compared to the end of the 2nd treatment month (p<0.001). No change seen in control group. | None reported. | Very high attrition/drop-out rate: intervention 20/38 (53%) dropped control 10/20 (50%) dropped. | Poor
| | Greece | | | | | 38 to exercise | Mean age: 11.9 (0.5) | Exercise: 2 month training program with four, 60 minute sessions per week. | | | | Detraining period not defined. Four month lead-in phase not described.
| | | | | | | 20 to control | Female gender: 0% | Sessions included warm-up, stretching, and aerobic exercise at 75% of physical work capacity. | | | | No analyses of between group differences.
| | | | | | | | Race: | Control: No specific training program.
| | | | | | | | Control group | Both groups advised not to change dietary habits or physical activity. Blood samples taken at baseline, after 15 days of training, after 1st and 2nd training month, at end of 1st month of detraining.
| | | | | | | | Mean age: 12.1 (0.6)
| | | | | | | | Female gender: 0%
| | | | | | | | Race:
Tonstad, 1996 ^80^ | Drug | Double-blind RCT of colestipol 10g once per day or 5 g twice per day versus placebo | Effectiveness of colestipol in treating FH. | | 67 adolescents | Adolescents age 10–16 referred to lipid clinic; all had two or more TC ≥239.75 mg/dL and TG≤116.01 mg/dL. | 74 targeted, 67 agreed to participate | 37 boys (58%); 29 girls | All subjects instructed to follow a diet: 30% calories from fat; <10% from saturated fat and <200 mg cholesterol/day. Assessed with 4 day weighed food record. | 1 Fasting TC, TG, HDL, calculated LDL, apolipoproteins A-I and B, serum carotenoids.; 2 Compliance; 3 Diet; 4 Growth | After 8 weeks: | Total of 7 subjects dropped out 4 in colestipol; 3 in placebo. 5 patients dropped out because they refused to swallow the drug; | placebo group was older and more advanced Tanner stage (p<0.05) | Poor
| | | | | Norway | | | mean age 13.2 | Subjects randomized to drug treatment got either colestipol 10g once per day or 5g twice per day × 8 weeks. | | 1 TC decreased by 14% in colestipol ( 8.16±1.47 pre vs. 6.99±1.46 post) vs 1% in placebo (7.69±1.26 pre vs 7.57±1.34 post), p≤0.01;; LDL decreased by 19.5% in colestipol (6.58±1.3 pre vs 5.27±1.29 post) vs 1% in placebo (6.13±1.18 pre vs. 6.01±1.32 post), p≤0.01.; HDL was not significantly different (colestipol 1.12±0.25 pre vs 1.19±0.35 post vs placebo 1.12±0.20 vs 1.18±0.23).; TG were not significantly different (colestipol 0.99±0.61pre; 1.15±0.90 post vs placebo 0.96±0.66 pre vs 0.84±0.36 post).; 2 Compliance was 68% in colestipol group vs 76% in placebo group NS.; 3 intakes of major nutrients and vitamins were similar in the groups; 4 Linear growth velocity was within reference range for Norwegian adolescents. 1 patient lost ≥1 kg during the study (24.5 kg/m2 pre and 21.3 kg/m2 post). | 2 dropped out because they had unexpectedly low lipid concentrations at randomization.
| | | | | | | | Tanner stage 2.6 | Open label trial after 8 weeks in which placebo group started colestipol for 52 weeks; colestipol group continued on colestipol. | | | 8 girls did not agree to continue in the open phase.
| | | | | | | | | | | | Of 51 in open phase, 42 completed 1 year.
| | | | | | | | | | | | 8 subjects in colestipol group had GI side effects attributed to the drug: 2 had constipation that improved with temporary dose reduction; 1 had dyspepsia and 1 had flatulence throughout entire study; 2 had intermittent nausea, 1 had temporary decrease in appetite; 1 had abdominal pain improved with dose reduction.
Tonstad, 1996 ^81^ | Drug | Random assignment to double-blind comparison | To determine the efficacy and safety of cholestyramine therapy in young children with familial hypercholesterolemia | 2 years: 1 year of diet for everyone; | Boys aged 6 to 11 years and girls aged 6 to 10 years with familial hypercholesterolemia in a referral lipid clinic | 1 Familial hypercholesterolemia diagnosed if TC > 260 mg/dl and triglyceride levels < 200 mg/dl, if 1 parent had baseline cholesterol ≥ 300 mg/dl and triglyceride levels < 200 mg/dl, or tendon xanthoma, or if autosomal dominant inheritance present in other members.; 2 Prepubertal girls aged 6 – 10, and prepubertal boys aged 6 – 11 who completed an initial medical evaluation and dietary session and had a parent who understood the diet.; 4 Height velocity score standard deviation score > -2.0.; 3 Those taking lipid-lowering drugs were required to discontinue doing so at least 4 weeks before study start; 4 Secondary hyperlipidemia ruled out by clinical and lab examination. | 96 randomized, | Drug group | After 1 year of a low-fat, low-cholesterol diet, children with LDL ≥ 190 mg/dl or ≥ 160 mg/dl in the presence of familial premature cardiovascular disease were randomly assigned to a double-blind comparison of 8 gm cholestyramine or placebo for 1 year. Dieticians reinforced the diet at each visit. Dietary composition assessed by a 7 day record, evaluated by FIBER. Assigned dose 8 gm/day, following 1 week build-up phase of 4 gm/day. Follow-up visits scheduled after 2, 5, 7, 9 and 12 months. Compliance assessed by counting leftover packages at each visit. | 1 Serum LDL; 2 Height velocity; 3 Erythrocyte folate; 4 Total plasma homocysteine; 5 Serum fat-soluble vitamins; 6 Side-effects | 1 Serum cholesterol decreased in drug group vs placebo after 2, 9 and 12 months (p<0.001) LDL decreased by -16.9% to -18.6% vs 0 to 1.5% (p=0.0001). Change in HDL level was no significant, and mean triglyceride levels remained unchanged in both groups. Apolipoprotein B levels were reduced in drug vs placebo groups (p=0.0001).; 2 No difference in mean height velocity standard deviation scores in those who hadn't started puberty; 3 No significant differences reported; 4 Total homocysteine level increased in drug group, and was negatively correlated with levels of erythrocyte and serum folate after 1 year.; 5 In drug group vs placebo, mean levels of 25-hydroxyvitamin D decreased (p=0.04); 6 In drug group, one girl had low folate and elevated homocysteine levels, and there was one case of intestinal obstruction caused by adhesions | In the drug group, folate defiency occurred in one subject, in whom the total homocysteine level increased concurrently. With the exception of modest decreases in levels of vitamin D during the winter, other nutritional deficiencies were not observed. | 1 High attrition: only 22/36 (61%) in drug group and 26/36 (72%) in placebo completed the study.; 2 Only about half the children were able to take cholestyramine in the amount prescribed, primarily because of unpalatability. | Fair
| | Norway | | 1 year randomized treatment phase | | | 36 to drug | Mean age: NR | | | | No adverse effects on growth and bone age evident.
| | | | | | | 36 to placebo | Female gender: 44%
| | | | | | | | Race: NR
| | | | | | | | Placebo group
| | | | | | | | Mean age: NR
| | | | | | | | Female gender: 33%
| | | | | | | | Race: NR
Walter, 1985 ^222^ | Diet and exercise combination | Randomized trials of school-based interventions | To assess the feasibility and effectiveness of a curriculum focused on nutrition, physical fitness, and smoking prevention in elementary schools | 5 years | 2,283 4th graders from 22 elementary schools in the Bronx, NY. | Assume all children at each school were eligible | 1,563 (68.5% participated in baseline examination. 1,115 of these (71.3% )were available at 1 year for follow up assessments. | mean age=9.1 years | Intervention schools received the “Know Your Body” curriculum each year starting in 4th grade and continuing until 8th grade; taught in usual classroom by regular teacher 2 hours/week for entire school year. | 1 HDL, TC; 2 Serum thiocyanate ponderosity index (derived from height and weight measurements); 3 Triceps skinfold thickness; 4 Post-exercise pulse recovery rate (recovery index).; 5 Systolic and diastolic BP | 1 Plasma TC: control (170.1 mg/ml±25.6 at baseline vs 171±28.3 at 1 year; intervention 173.3±26.6 at BL vs 172.7+27.7 at year 1). This is a 0.4% decrease in the intervention group compared with 0.5% increase in control group.; 2 Plasma HDL: control 56.8±12.8 at BL vs 60.5+12.3 at 1 year; intervention 54.4±11.3 at BL vs 59.5±13.5 at 1 year.; 3 TC/HDL ratio control 3.1±0.8 at BL vs 2.9±0.7 at 1 year; intervention 3.3±1.2 at BL vs 3.0±0.8 at 1 year. | Significant impact on the classroom teacher (time away from usual material) | Screening for risk factors was also done in control school children. | Fair
| | | | | | | Final n: 805 intervention and 310 control | male 51.4% | Teachers trained by research staff in 3 half-day teacher workshops on curriculum implementation. | | Adjusting for age, gender, race and BL risk factor level, TC difference between Intervention and Control groups at 1 year was -3.1 (p=0.032); HDL difference was +1.0 (p=0.175); ratio difference was -0.10 (p=-0.063).
| | | | | | | | race: | Adherence to teaching protocols monitored by classroom visits from research staff and attendance at training workshops. | | Intervention was successful in reducing systolic and diastolic BP.
| | | | | | | | black 48.9% | Curriculum based on social learning, encouraging adoption of healthy behaviors: AHA prudent diet/AHA
| | | | | | | | Hispanic 23.2% | Committee Report (1978); regular exercise program; resisting social pressures to smoke.
| | | | | | | | white 24.6% | Curriculum materials included: teacher guides, student workbooks and worksheets, health passports, videotapes, posters and calendars.
| | | | | | | | 3.3% other (Asian or Pacific origin primarily)
| | | | | | | | median family income $22,126
Wheeler, 1985 ^82^ | Drug | DB randomized cross-over trial | To evaluate the use of benafibrate for lower cholesterol in children. | 6 months: 3 month arm of either placebo or medication. | 14 children with FH | Diagnosis of FH established by TC>259.09 mg/dL, a type IIa pattern on lipoprotein electrophoresis and normal fasting TG (<58 mg/dL) in the patient; with either similar lipoprotein abnormalities in one of the parents or premature CHD death in a parent and a similar lipid abnormality in another close relative. | 14 children; all had previously been treated with dietary measures (inadequate to control cholesterol), had been recommended cholestyramine but refused to take it. | NR | 1 Children asked not to change their diets; 2 10–20 mg/kg/day given bid (in 100 mg tablets) given for 3 months | 1 TC, HDL, TG; 2 Urine bezafibrate to assess compliance. | 1 Mean plasma TC on bezafibrate was 22% lower than while on placebo (7.8±1.0 vs 10.0±1.6, p<0.0001) and 16% lower than in the period before the trial (7.8±1.0 vs. 9.3±1.5,p<0.001).; 2 Mean HDL rose 15% while on bezafibrate compared with placebo (p<0.01); increased 25% compared with pre-trial values (p<0.001).; 3 Mean plasma TG fell 23% while on bezafibrate compared with placebo (pNS), and 33% compared with pre-trial values (p<0.05).; 4 In all but one case bezafibrate was detected in the urine on all measurements during the active drug phase, and in none of the measurements while on placebo. | 1 One child had high alk phosphatase at the end of 3 months of bezafibrate (had a slight intercurrent infection, and values returned to normal); 2 Another child had slight transient rise in alanine transaminase during first 2 months on bezafibrate but values were normal by end of 3rd month; 3 growth was satisfactory throughout trial; 4 no other reports of adverse effects | All children declared a strong preference for this drug as compared with cholestyramine used previously. | Poor
| | | | | | | | | | | | | No results prior to cross-over.
| | | | | | | | | | | | | No wash out period between cross over periods.
Wiegman, 2004 ^37^ | Drug | RCT of drug | To determine the 2-year efficacy and safety of pravastatin therapy in children with familial hypercholesterolemia (FH) | 2 years | FH children ages 8 to 18 recruited from academic medical referral setting | 1 Parent with clinical or molecular diagnosis of FH;; 2 Two fasting samples with LDH-C levels of 155 mg/dL or more and triglyceride levels below 350 mg/dL;; 3 Adequate contraception for sexually active girls;; 4 No drug treatment for FH or use of plant sterols;; 5 No homozygous FH;; 6 No hypothyroidism;; 7 No abnormal levels of muscle or liver enzymes. | 214 randomized, 106 to drug | Pravastatin group | After initiation of a fat restricted diet for 3 months or more and encouragement of regular physical activity, randomized to pravastatin 20 – 40 mg/day or placebo. Evaluated every 6 months for 2 years. | 1 Change from baseline mean carotid IMT; 2 Growth, maturation and hormone level measurements; 3 Changes in muscle and liver enzyme levels | 1 Pravastatin: trend toward regression, mean [SD], -0.010 [0.48]mm; p=.049. Placebo: trend toward progression, 0.005 [0.044]mm;p=.28.; Mean change in IMT between the groups significant, p=.02. Greater reduction in mean LDL with pravastatin vs placebo (-24.1% vs 0.3% respectively, p<.001.; 2 No differences observed in growth, endocrine function parameters, Tanner staging scores, onset of menses or testicular volume.; 3 No differences observed in muscle or liver enzyme levels. | No significant differences between groups for “all endocrine functionp arameters.” In the placebo group, 1 child developed extreme CPK elevation which returned to normal 1 week after stopping the study regimen. In the placebo group, AST elevation (more than 3-fold) occured twice. Elevations in CPK occured 4 times in the treatment group and three times in the placebo group. “No adverse effects on growth, sexual maturation, hormone levels, or liver or muscle tissue.” | 2 year follow-up | Good
| | Netherlands | | | | | 108 to placebo | Mean age: 13.0 | | | | | Well-designed
| | | | | | | | Female gender: 57%
| | | | | | | | Race: NR
| | | | | | | | Placebo group
| | | | | | | | Mean age: 13.0
| | | | | | | | Female gender: 57%
| | | | | | | | Race: NR
Williams, 1995 ^229^ | Diet | Randomized single blind trial of psyllium | to compare fiber enriched Step I diet to usual Step I diet to lower cholesterol in children with borderline high and high blood cholesterol levels | 12 week | Children ages 2–11 referred to lipid clinic | Serum cholesterol >170 mg/dL and LDL >110 mg/dL | 58 children | 5% of children had a parent and 52% had a grandparent with premature onset of CHD (<55 yrs); 48% had a parent with blood cholesterol >200 mg/dL | Age 2–11 years (mean age in Step I group 94.7mo (n=24); in fiber group 82.5mo n=26) | 1 box of cereal per day × 1st 3 weeks, then 2 boxes/day. Children age 2–5 consumed only 1 box/day throughout study. Fiber group cereal contained 3.2 g soluble fiber per serving; control cereal contained 0.5 g soluble fiber per serving. Both identical boxes, manufacturer. | Lipoprotein results n=50; anthropometric and lipid results N=49. | Growth velocity, height, weight skinfold thickness and BMI were monitored and no differences between treatment and control group were noted. | Authors state that 8 children who did not complete the study were no significantly different than the remaining 50. | Poor
| | | | | | | | | | | After 12 weeks:
| | | | | | | | | | | 1 TC 196 mg/dL step I (-5.5%) vs 197mg/dL (-9.6%) fiber group; p<0.05 between groups, p<0.01 within Step I, p<0.001 with fiber.; 2 HDL 49.6+8.8 mg/dL step I (+1.5%) vs 45.01+13.57mg/dL (+4%) fiber group, NS between groups or within groups.; 3 LDL 124.3+25 step I (-6.4%) vs. 126.76 (-15.7%); p<0.001 between groups, NS change in step I group, p<0.01 for change in fiber group.; 3 TG 113.9+47 mg/dL step I (-15.3%) vs 128.9+55mg/dL (-8.9%) fiber group (p<0.001 between groups; NS change within groups); 4 TC/HDL and LDL/HDL ratios also had significant improvements (-17.9% and -21.1% respectively) in the fiber group vs -4.7% and -7.4% in Step I group, P<0.001 for between group difference.

Evidence Table 5. Adverse Effects of Interventions

Author, year | Title | Type of Study/Setting | Aims | Duration of Study | Main Eligibility Criteria | Enrolled | Demographics | Interventions/Exposures | Adverse Effects | Compliance/Tolerance | Comment
Statins
Clauss, 2006 ^38^ | Lipid-lowering Effects of Lovastatin in Post-menarchal Girls with heterozygous Familial Hypercholesterolemia | RCT in Post-menarchal girls with heFH | NR | 24 weeks | HeFH; baseline LDL required was 160–400 mg/dL and parental history of familial hypercholesterolemia. | 54 girls ages 10–17 at least 1 years post-menarche | - | Lovastatin 20 mg for 1st 4 weeks, then 40 mg thereafter | “Adverse reactions to lovastatin were generally mild and transient.” Patients treated with lovastatin had an adverse experience profile generally similar to that of patients treated with placebo. In this limited controlled study, there was no detectable effect on menstrual cycle length in girls. Adolescent females should be counseled on appropriate contraceptive methods while on lovastatin therapy." | NR
Couture, 1998 ^66^ | Association of specific LDL receptor gene mutations with differential plasma lipoprotein response to simvastatin in young French Canadians with heterozygous familial hypercholesterolemia | RCT | To determine whether the nature of the LDL receptor mutation affects the response to simvastatin. To describe the different responses to simvastatin of plasma lipids, lipoproteins, and apoprotein levels among 3 genetically differentiated groups of heterozygous FH children and adolescents. | 6 weeks | 1 Heterozygous FH patients with 1of 3 mutations in the LDL receptor gene.; 2 Aged 8 – 17; 3 Weight ≥ 27 kg; 4 Plasma levels persistently above 95th percentile for age and sex while maintaining a lipid-lowering diet.; 5 No concomitant conditions, such as diabetes, anorexia, thyroid disorders | 63 FH patients at university research clinic | 37 boys and 26 girls | Individual screening with medical history, physical exam, interview with dietician, and blood sampling 6 weeks prior to study entry. All lipid-lowering medications discontinued at screening entry. Four weeks placebo run-in, followed by randomization to double-blind active treatment, 20 mg/d simvastatin or placebo for 6 weeks at 3:1 ratio. Compliance verified by tablet count at weeks 0, 2, 4, and 6. Patients questioned about adverse or unusual signs or symptoms at all clinic follow-up visits (weeks 0, 2, 4, and 6). Patients counseled by dietician to follow American Heart Association phase I diet throughout trial. | Patients were questioned about any adverse or unusual signs or symptoms, but none were suggested. Compliance to the prescribed medication was assessed weekly by tablet counting, and there was no significant difference in compliance among the mutation groups. | NR
| | Laval University Lipid Research Clinic, Quebec City, Canada | | | | | | Routine hematology and blood chemistry test results were obtained at week -6 and 6.
de Jongh, 2002a ^68^ | Early statin therapy restores endothelial function in children with familial hypercholesterolemia | RCT with an additional arm of non-FH controls. USA. | To determine whether simvastatins improves endothelial function in children with familial hypercholesterolemia (FH) | 28 weeks | Children with heterozygous FH as defined by:; 1 LDL>95 percentile for age/gender;; 2 Documented family history of hyperlipidemia with LDL>95 percentile for age/gender after treatment;; 3 Personal diagnosis by detection of mutation at the LDL receptor gene | 50 heterozygous FH children plus 19 non-affected controls. | HeFH patients ages 9–18. | 50 heterozygous FH children randomized to simvastatin or placebo in 3:2 ratio. An additional 19 healthy non-FH siblings also used as controls. | There were no significant differences with regard to safety measurements (ALT, AST, and CK) between simvastatin and placebo FH groups, and no adverse events were reported. | Not reported.
| | | | | | 28 in FH simvastatin group, 22 in FH placebo group, 19 non-FH controls. | FH simvastatin group Mean age: 14.6+2 Female gender: 13 (42%) Race: NR.
| | | | | | | FH placebo group Mean age: 14.6+2.5. Female gender: 11 (50%) Race: NR.
De Jongh, 2002b ^69^ | Efficacy and safety of statin therapy in children with familial hypercholesterolemia | Double-blind, placebo controlled multi-center | To evaluate LDL-cholesterol-lowering efficacy, overall safety, tolerability and the influence of growth and pubertal development of simvastatin in a large cohort of boys and girls with heterozygous familial hypercholesterolemia (heFH). | 48 weeks of intervention after 4 week run-in | 1 Age 10 – 17; 2 LDL-C 4.1 – 10.3 mmol/L; 3 Parent with confirmed diagnosis of heFH.; 4 Boys: Tanner stage II or above; Girls: postmenarchal for at least 1 year before study initiation | 173 | 98 boys and 75 girls | After 4 week placebo/diet run-in, randomization to active treatment or matching placebo in 3:2 ratio and stratified by sex. Simvastatin (drug) started at 10mg/day and increased at 8 week intervals to 20 and then 40 mg/day for the remainder of the study (period 1, 24 week duration) and for a 24 week extension (period 2). Office visits every 4 weeks. Menstrual cycle monitored throughout study period and Tanner staging used to assess pubertal development. | 223 assessed for eligibility, 175 randomized - 69 to placebo, 106 to control. 5 of placebo discontinued: 1 lost to follow-up, 2 withdrew consent, 2 for other reasons. 5 of drug discontinued: 1 to mononucleosis, 1 to protocol deviation, and 3 to consent withdrawal. No serious AEs. Total drug group clinical AEs included: abdominal pain (3), chest pain (1), flatulence (1), myalgia (2), headache (4), sleep disorder (1), weight gain (1), pruritus (1). Total drug group lab AEs: increased ALT (3), increased AST (3), increased CK (1). No deleterious effects on growth or pubertal development. | 101/106 drug completed period 1 and 83/106 completed period 2 (78%). 56/69 placebo(81%) completed period 2.
| | RCT | | | Exclusion: familial hypercholesterolemia, secondary hyperlipidemia
| | 9 international sites
De Jongh, 2003 ^70^ | Quality of life, anxiety and concerns among statin-treated children with familial hypercholesterolemia and their parents | Cross-sectional study; lipid clinic, Amsterdam | To determine whether statin therapy influenced the quality of life and anxiety levels of the FH children and their parents, and to assess the specific FH-related concerns of these families. | 0 (cross-sectional survey) | Children who had received 1 year of statin therapy and their parents were recruited from the Paedriatric Lipid Clinic of the Emma Children's Hospital of the University of Amsterdam. Inclusion criteria: age 10–18 y, LDL >158 before statin therapy and one parent diagnosed with FH. | 69 children from 51 families | Mean age 15.3 | Children had been treated with statins for 1 year prior to the study. The children and their parents were administered questionnaires during a visit to the Lipid Clinic while an investigator explained the questionnaire and stayed in the room. The instruments used: the NO AZL Children's Quality of Life (TACQoL), the Trait Anxiety Inventory for children, and a specific FH survey. A random sample of 200 healthy Dutch children aged 12–16 served as a control for the TACQoL and Trait Anxiety Inventory surveys. | There were no significant differences between the children with FH and their healthy peers on the health-related quality of life and anxiety questionnaires. | Not reported. | Methods of data collection of control subjects was not adequately described.
| | | | | | | 47.8% female
Dirisamer, 2003 ^70^ | The effect of low-dose simvastatin in children with familial hypercholesterolemia: a 1-year observation | Single-center, open-label, diet-controlled study. | To investigate the efficacy and safety of low-dose simvastatin for 1 year in children and adolescents (aged 10–17) with FH. Safety assessment included weight, height, and lab values. | 18 months: 3-month diet, followed by drug therapy | Boys and girls aged 10–17 with LDL >190 and a BMI between 5th and 85th percentile for age were included. | 20 | Mean age 13.0, range 10–17 | Simvastatin dosage begin at 5 mg/day for patients with LDL < 220, and 10 mg/day for patients with LDL >220. If a range for LDL of 150–170 was not reached within the first 8 weeks, the daily dosage was increased stepwise up to 20 mg/day. | 3 patients had abnormal levels of safety parameters: 2 patients (one receiving 5 mg/day and the other 10 mg/day) showed slightly higher values of CK. One (10 mg/day) expressed transiently elevated concentrations of ALAT (GPT) and GCT. | “Simvastatin was well tolerated. Side-effects were few and equally distributed among the three dosage periods.”
| | | | | | | 60% female | Safety was assessed at follow-up visits every 4–8 weeks. Each time patients were questioned about any adverse or unusual signs or symptoms. Lab parameters include routine hematology and biochemistry, including blood urea nitrogen, creatinine, electrolytes, total protein, albumin, fasting glucose, complete blood count, AST, ALT, alkaline phosphatase, CK, and total and direct bilirubin. | Two boys (one 5 mg/day and the other 10 mg/day) suffered from headache in the morning of the first days treatment but which disappeared after a couple of days.
| | | | | | | | | One girl (5 mg/day) reported myalgia for about 2 weeks.
| | | | | | | | | Two other patients (one male 10 mg/day, one female 5 mg/day) had gastrointestinal complaints, which both resolved after 2 days without changing the medication.
| | | | | | | | | There was no difference in mean BMI between baseline and 1 year.
Ducobu, 1992 ^243^ | Simvastatin use in children | Open-label | To describe the long-term efficacy and safety data (24–36 months) in 32 hypercholesterolemic children younger than 17 years. | 24–36 months | Male or female children with total cholesterol >300 mg/dL after diet therapy for 6 months. | 32 | Age <17 | Children under age 10 started simvastatin at an initial dose of 5 mg/day. Titration to 10 mg daily after 4 weeks and to 20 mg after another 4 weeks was possible. Older children began on 10 mg/day, increased to 20 mg/day after 6 weeks, and if necessary to 40 mg/day after an additional 6 weeks. | Transaminases, alkaline phosphatase, and creatinine phosphokinase were measured at weeks 4, 12, 26, 52, 78, and 104, No significant changes were detected. Transient increases in 1 transaminase, and 2 CPK measurements. | Author states “well tolerated” | This study was published only as a letter
| | | | | | | 22 (68.8%) male | Mean dose: 16 mg/day. | Growth: Children for whom height (n=12) and weight (n=16) were available remained in the growth percentages they had been in at baseline.
| | | | | | | 10 (31.2%) female
Hedman, 2003 ^240^ | Pharmacokinetics and pharmacodynamics of pravastatin in children with familial hypercholesterolemia | Open-label clinical follow-up trial Finland | To determine the single-dose pharmacokinetics and the lipid-lowering effect and safety of short-term use of pravastatin in children with heterozygous FH. | 8 weeks | 1 Age 4 or older; 2 Total serum cholesterol > 6 mmol/L despite dietary interventions; 3 Diagnosis of FH confirmed by LDL receptor mutation analysis or lymphocyte test; 4 Healthy, with no use of cholesterol lowering medication before study | 20 | 13 girls and 7 boys with heterozygous FH. | 10 mg pravastatin orally per day for 8 weeks. | Few transient adverse events. No increase in serum alanine aminotransferase, creatine kinase, or creatinine. | Author states “well-tolerated without any clinical significant side effects” | Duration only 8 weeks. Dose too low to achieve therapeutic response except for 2 patients - therefore, AE's associated with a therapeutic dose were not adequately assessed.
| | | | | | | Age range: 4.9 – 15.6 years. | | Adverse events reported in questionnaires: abdominal pain (1), loose stools (1), headache (4), sleep disturbance (2), muscle tenderness or pain in rest (1), muscle tenderness or pain associated with physical training (1). All symptoms mild and disappeared during first 4 weeks of treatment.
Knipscheer, 1996 ^71^ | Short-term efficacy and safety of pravastatin in 72 children with familial hypercholesterolemia | double-blind, randomized placebo controlled study, children stratified by age. | To assess the safety, tolerability and efficacy of pravastatin for HeFH | 12 weeks, following an 8 week diet and placebo run-in period. | Children with “known heterozygous FH” were eligible. HeFH defined as plasma LDL above 95th percentile for age and sex during lipid-lowering diet AND hypercholesterolemia in siblings, parents or grandparents, or clinical manifestations of premature atherosclerosis prior to age 50 in 1st/2nd degree relatives. | 72 children with HeFH | 25 male; 47 female | Pravastatin 5, 10 and 20 mg/day | Total number adverse events P- 9, 5 mg/day - 3, 10 mg/day - 6, 20 mg/day - 1. | Compliance was 93%
| | 4 arms (3 doses of pravastatin, 1 placebo) | | | Exclusion: | | 66/72 White; 5/72 Black. | | List: rash, fatigue (P only), nose bleeding, headache, diarrhea (P only), dyspepsia (P only), nausea/vomiting, abdominal pain, myalgia (P only).
| | Lipid clinic, The Netherlands | | | 1 Major surgery within the past 3 months; 2 Use of medications interfering with lipid metabolism (anticonvulsants, oral contraceptives, corticosteroids, fibric acid derivatives or immunosuppressants).; 3 Hepatic or renal dysfunction | | Mean age 11.9–12.1 across | | Laboratory safety measurements did not show significant changes in any of the groups between the end of the treatment period and baseline. However CK abnormal in 8 of P, 6 of 5mg/day, 11 of 10 mg/day and 8 of 20 mg/day.
| | | | | | | 4 groups. | | Cortisol abnormal in 2 of P, 2 of 5 mg/d, 5 of 10 mg/d, 3 of 20 mg/d
Lambert, 1996 ^72^ | Treatment of familial hypercholesterolemia in children and adolescents: effect of lovastatin | RCT of drug | To determine the efficacy, safety and tolerance of short-term administration of lovastatin in a male pediatric population with severe FH, and to evaluate dose-response relationship. | 8 weeks | 1 Weight 27 kg or more; 2 Plasma LDL above 95th percentile for age while on lipid-lowering diet; 3 History of unsuccessful treatment with bile acid-binding resins; 4 Family history of atherosclerosis at or before age 50; 5 Documented family history of hyperlipidemia with LDL > 95th percentile for age and sex before treatment or a personal diagnosis of FH substantiated by LDL receptor activity or mutation.; 6 No significant concomitant conditions; 7 Weight and height not 3 – 97th percentile for age | 69 randomized, | 10 mg/day group | After pre-study visit and lab tests, all lipid-lowering medications were discontinued at least 8 weeks before study start, with no lipid-lowering therapy allowed other than that permitted by study protocol. Placebo given weeks -4 to 0, followed by randomization to double-blinded active treatment of lovastatin at 10, 20, 30 or 40 mg/day for 8 weeks. Medication dispensed at weeks -4, 0, and 4. Compliance verified by tablet count at weeks 0, 4 and 8. | No serious clinical adverse effects reported. Three patients had > asymptomatic elevations in creatine kinase, which spontaneously returned to normal, with no action required regarding the drug. | Drug well-tolerated. 85% of patients took at least 70% of the prescribed dose during the active treatment period. | No separate control group: patients served as own controls
| | multicenter: 6 sites in Canada | | | | 17 to 10 mg/day group | Mean age: 12.5 (2.4) | Clinic follow-up visits at weeks -4, -2, 0, 2, 4, 6, and 8. Complete physical exam at weeks 0 and 8. Ophthalmologic exam during placebo period and within 8 weeks of study exit. Patients continuously counseled by dietician to follow lipid-lowering diet throughout the trial. Daily food records completed by patients for 3 consecutive days and reviewed by a dietician at weeks -4, 0, 4, and 8.
| | Boys aged 17 or younger with heterozygous FH | | | | 18 to 20 mg/day group | Female gender: 0
| | | | | | 19 to 30 mg/day group | Race: 94.1% white
| | | | | | 15 to 40 mg/day group | 20 mg/day group
| | | | | | | Mean age: 12.7 (1.6)
| | | | | | | Female gender: 0
| | | | | | | Race: 100% white
| | | | | | | 30 mg/day group
| | | | | | | Mean age: 13.3 (2.7)
| | | | | | | Female gender: 0
| | | | | | | Race: 94.7% white
| | | | | | | 40 mg/day group
| | | | | | | Mean age: 12.9 (2.7)
| | | | | | | Female gender: 0
| | | | | | | Race: 93.3% white
McCrindle, 2003 ^76^ | Efficacy and safety of Atorvastatin in children and adolescents with familial hypercholesterolemia or severe hyperlipidemia: a multicenter, randomized, placebo-controlled trial | RCT of drug | To determine the safety and efficacy of atorvastatin (10 to 20 mg) in children and adolescents with familial hypercholesterolemia (FH) or severe hypercholesterolemia | 26 weeks | 1 Known FH or severe hypercholesterolemia and LDL-C>190mg/dL or LDL-C > 160 mg/dL and a family history of FH or documented premature CV disease in a 1st or 2nd degree relative;; 2 TG < 400 mg/dL;; 3 >Tanner stage II;; 4 Not premenarche, pregnant or breastfeeding;; 5 Testicular volume > 3cm3 after age 12;; 6 Weight between 10th and 95th percentile for age;; 7 No liver or kidney disease; 8. No known sensitivity to statins; 8 No known sensitivity to statins | 187 randomized, | Atorvastatin group | After a 4 week baseline/placebo phase in which subjects were instructed to follow the NCEP step 1 diet, those whose LDL-C remained > 160 mg/dL and had TG < 400 mg/dL at week -2 were randomly assigned in 3:1 ratio to receive 26 weeks double blind treatment with drug (10mg/d) or placebo. Drug could be titrated to 20 mg/d at week 4 for those not at LDL-C < 130 mg/dL. Those completing double-blind were eligible to continue treatment for 26 weeks with open label atorvastatin (10 mg/d). | No significant adverse effects documented. Incidence of treatment-related adverse events during double-blind: 7% in drug vs. 4% in placebo group (p=.7) Most adverse effects were mild or moderate. Drug had no effect on sexual development. | Drug tolerated as well as placebo.
| | 20 centers world-wide (US, Canada, Europe, South Africa) | | | | 140 to drug | Mean age: 14.1 (2.0) | | Labs: 1% on atorvastatin had elevated AST, and 1% had elevated ALT.
| | Children aged 10 to 17 with FH or severe hypercholesterolemia | | | | 47 to placebo | Female gender: 32%
| | | | | | | Race: W: 94%
| | | | | | | B: 1.4%
| | | | | | | A: 1.4%
| | | | | | | Placebo group
| | | | | | | Mean age: 14.1 (2.2)
| | | | | | | Female gender: 28%
| | | | | | | Race: W: 87%
| | | | | | | B: 2.4%
| | | | | | | A: 2.4%
Sinzinger, 2004 ^242^ | Professional athletes suffering from familial hypercholesterolemia rarely tolerate statin treatment because of muscular problems. | Descriptive study in professional athletes with FH; | To monitor the experiences of 22 adolescent and young-adult professional athletes with FH, in whom treatment with statins was attempted. | 8 years | Patients were considered as professional athletes when they had attended an Austrian championship at any age class during the last 2 years or were playing gin the top two leagues of their respective discipline. All were suffering from FH as diagnosed at the receptor level. Testing for anabolic steroids was done in all athletes to exclude any possible influence. | 22 | Mean age 24.1 (range 15 – 27) | No drugs including vitamins were taken for at least 4 weeks. The lowest available dose of statin was used as a starting dose. Subjects were given atorvastatin, fluvastatin, lovastatin, pravastatin, or simvastatin. Switching patients who tolerated a statin occurred only if they did not achieve target values. The shortest duration of treatment before switching was 8 weeks. Safety was assessed by blood samples for CK and liver enzymes (GOT, GPT, gamma-GT) drawn regularly | Among 87 periods of attempted statin therapy, the treatment was tolerated only 16% of the time. Muscle pain (weakness, cramps, aches, others) was reported in 84% of periods of statin therapy. The mean time of onset of muscle pain was 8.3 days (range 2 to 18 days). | When initiating a statin therapy, only 3 out of 22 athletes (11%) tolerated the chosen drug. Another 3 patients tolerated at least one statin. Only two athletes tolerated all the statins used.
| | Austria | | | | | 31.8% female | | Only two of the 22 subjects tolerated each of four statins (lovastatin, pravastatin, atorvastatin, and simvastatin. Two other patients tolerated atorvastatin and fluvastatin, but experienced muscle pain on lovastatin, pravastatin, and simvastatin. Three patients had elevated CK with one or more statins.
| | | | | | | | | An increase in liver enzymes was not observed in any of the athletes.
Stefanutti, 1999 ^244^ | Diet only and diet plus simvastatin in the treatment of heterozygous familial hypercholesterolemia in childhood | Non-randomized controlled trial | To investigate the effect of hypolipidemic treatment - low cholesterol diet only (group A) or diet plus 10 mg/day simvastatin (Group B). | 12 months | Pediatric patients with heterozygous FH | 16 | Age 7–12, mean 8.75 | Patients were submitted to a 3-month washout (free diet). Then they were given an AHA Step 2 diet for 6 months: cholesterol <=200 mg/day, saturated fats <=10% of calories, total fats <=30% of total calories. After 6 months they were divided in two groups, matched for sex, age, and body mass index: Group A (n=8) received only the diet. Group B (n=8) was given 10 mg/day simvastatin. Followup lasted 1 year for both groups. | No adverse effects were observed during the therapeutic approach with diet, and with diet plus simvastatin, on relatively long-term treatment. | Patients showed good compliance with the treatment. | Small sample size
| | | | | | | 7 (44%) males
| | | | | | | 9 (56%) females
Stein, 1999 ^78^ | Efficacy and safety of Lovastatin in adolescent males with heterozygous familial hypercholesterolemia | RCT of drug | To assess the lipid-lowering efficacy, biochemical safety, and effect on growth and sexual development of lovastatin in adolescent boys with HeFH | 48 weeks | 1 Followed American Heart Association (AHA) pediatric diet for at least 4 months; 2 LDL-C 189 mg/dL – 503 mg/dL; 3 At least 1 parent had an LDL-C of at least 189 mg/dL not due to secondary causes or LDL-C values were 220 – 503 mg/dL or their LDL-C values were 220 – 503 mg/dL and a parent died of CAD with no available lipid values.; 4 No homozygous FH, underlying disorders known to produce secondary LDL-C elevations; 5 No disorders affecting triglyceride-rich lipoproteins; 6 After the trial began, FDA requested only subjects who had Tanner stage 2 at entry be included in the trial.; 7 No delayed puberty shown by testicular volume ≤ 3 cm after age 12; 8 Weight ≥ 32 kg and between 10th – 95th percentile for age | 132 randomized, 67 to drug | Lovastatin group | All received formal dietary reinstruction, were monitored, and determined to be stable following a AHA pediatric diet for at least 8 weeks before randomization. Placebo was administered week -4 to week 0. All subjects continued diet instruction, monitoring, and evaluation throughout the study. | 1 1 drug and 2 placebo subjects discontinued due to AE's. No clinically significant AE's. 6 withdrew in lovastatin, 1 due to AEs: increased bruising and purpura 16 withrew in placebo, 2 due to AEs: skin rash and myalgia; 2 Drug had no significant effect on growth parameters at 24 or 48 weeks; 3 No difference between drug and placebo in testicular volume, Tanner staging, testosterone, or LH level. DHEAS increased 18% in the drug group compared to 5% in the placebo group. (p=.03); 4 Reduction of tocopherol in drug group at week 48 (p=.002), consistent with decrease in LDL-C. In both groups, increase in ALT from baseline, with no differences between groups at week 48 (p=.20), although increase was significant for each group (drug, P<.001; placebo, P=.008). No consistent changes in AST or CK. Report of infrequent, sporadic, nonsustained CK elevations in response to exercise. | 6 withdrew in lovastatin, 1 due to AEs: increased bruising and purpura | Good
| | 14 pediatric clinics in the USA and Finland | | | | 65 placebo | Mean age: 13.3 (0.3) | Randomized to drug: Lovastatin, starting at 10 mg/day, with a forced titration at 8 and 16 weeks to 20 and 40 mg/day, respectively. 40 mg/day weeks 25 – 48. | | 16 withrew in placebo, 2 due to AEs: skin rash and myalgia
| | | | | | | Female gender: 0% | Randomized to placebo: Matching placebo tablets
| | | | | | | Race: 93% of all were white
| | | | | | | Placebo group
| | | | | | | Mean age: 13.1 (0.3)
| | | | | | | Female gender: 0%
| | | | | | | Race: 93% of all were white
Wiegman, 2004 ^37^ | Efficacy and safety of statin therapy in children with familial hypercholesterolemia | RCT of drug | To determine the 2-year efficacy and safety of pravastatin therapy in children with familial hypercholesterolemia (FH) | 2 years | 1 Parent with clinical or molecular diagnosis of FH;; 2 Two fasting samples with LDH-C levels of 155 mg/dL or more and triglyceride levels below 350 mg/dL;; 3 Adequate contraception for sexually active girls;; 4 No drug treatment for FH or use of plant sterols;; 5 No homozygous FH;; 6 No hypothyroidism;; 7 No abnormal levels of muscle or liver enzymes. | 214 randomized, 106 to drug | Pravastatin group | After initiation of a fat restricted diet for 3 months or more and encouragement of regular physical activity, randomized to pravastatin 20 – 40 mg/day or placebo. Evaluated every 6 months for 2 years. | No differences between groups in changes in height, weight, BMI, body surface area, testis volume, liver and muscle enzymes, and endocrine function parameters (corticotropoin, cortisol, DHEA-S, FSH, LH, thyrotropin, 17b-estradiol, testosterone), and Tanner Stage. | Tablet counting revealed that 84% of tablets were taken; mean visit attendance per child was 95% of all study visits. | 2 year follow-up
| | Netherlands | | | | 108 to placebo | Mean age: 13.0 | | One child had an asymptomatic but extreme CPK elevation (16400 U/L) after 168 of placebo treatment. CPK level decreased to normal within 1 week of stopping treatment. | | Well-designed
| | FH children ages 8 to 18 recruited from academic medical referral setting | | | | | Female gender: 57% | | No differences observed in growth, endocrine function parameters, Tanner staging scores, onset of menses or testicular volume.
| | | | | | | Race: NR | | 3. No differences observed in muscle or liver enzyme levels.
| | | | | | | Placebo group
| | | | | | | Mean age: 13.0
| | | | | | | Female gender: 57%
| | | | | | | Race: NR
Bile-acid binding resins
Curtis, 1991 ^245^ | Loss of dental enamel in a patient taking cholestyramine | Case report | Report of a case of extensive loss of dental enamel in a young boy, thought to be attributed to mixing the cholestyramine in Kool-Aid and swirling the mixture in the mouth before swallowing. | 2 years of treatment with cholestyramine | N/A | 1 | 7-year-old boy, LDL 240 mg/dL. | The family was instructed to follow AHA Step 1 diet, and an aerobic exercise program. After 6 months the patient's LDL was 255 mg/dL, and so was given 4g of cholestyramine daily twice daily for the next 2 years. The parents stated that they had mixed the cholestyramine in Kool-Aid to improve the taste, and the patient stated that he had “swished” the mixture in his mouth for 10 to 15 minutes before swallowing. | After 2 years, the parents noted a change in the color of the patient's teeth, and a subsequent dental examination revealed extensive loss of enamel. Serum calcium, phosphorus folate, and vitamin B12 values were normal. Results of a radioactive bone mineral analysis were normal. | NR | Case report
| | | | | | | | | KoolAid has a pH of 2.9 after water is added; the pH decreases to 2.4 after cholestyramine is added.
Farah, 1977 ^246^ | A study of the dose-effect relationship of cholestyramine in children with familial hypercholesterolemia. | Descriptive study | 1) To determine the optimal dose of cholestyramine required in children to significantly lower their LDL and cholesterol;; 2) to relate this dose to their body weight and pre-treatment levels of LDL and cholesterol;; 3) to study the effectiveness of a dose given twice daily; and; 4) to monitor for potential side-effects, such as fat soluble vitamin malabsorption. | 21 days | Children and young adults with HeFH were identified through screening children of affected parents followed at the Lipid Research Clinic. | 20 | Mean age 15 y | 13 patients were maintained on an outpatient isocaloric diet (<200 mg cholesterol with polyunsaturated: saturated fat ratio of 2.0). The diet was continued for 21 days. After 5 days, cholestyramine was started at 1 g/day and increased by 1 g/day up to a total of 16 g/day given twice daily. | None of the patients on cholestyramine demonstrated any significant side-effects such as fat-soluble vitamin malabsorption. | NR | Reports on different AEs in the same study as Farah, 1997 below.
| | Lipid clinic, Johns Hopkins Hospital | | | | | | In another group, 7 children received the same dietary treatment, and started on a dose of cholestyramine predicted by a regression based on post-diet level of LDL: either 4 g, 8 g, or 16 g/day.
Farah, 1977 ^247^ (See Farah, 1977 above) | Dose-effect relation of cholestyramine in children and young adults with familial hypercholesterolemia | Descriptive study | 1) To determine the minimum dose of cholestyramine required to lower significantly the plasma LDL cholesterol and total cholesterol in young patients with FH;; 2) to relate this dose to their body-weight and pretreatment concentrations of LDL cholesterol and total cholesterol;; 3) to study the effectiveness of the dose given twice daily;; 4) to monitor for immediate side-effects such as gastrointestinal symptoms and folate deficiency. | 21 days: 5 days of baseline evaluation followed by a 16-day period of drug treatment. | Criteria for FH were the presence of xanthomas and hyperbetalipoproteinaemia in the parent, or the transmission of hypercholesterolemia and hyperbetalipoproteinemia through many generations. The latter conditions were defined by concentrations of plasma total and LDL cholesterol above 95th percentiles, adjusted for age and sex. | 20 | Mean age 15 ±5 S.D. years | Patients had been treated for a minimum of 6 weeks on a therapeutic outpatient diet. NIH-type II diet was calculated daily for each of the children during admission to the metabolic unit. | In one patient, febrile gastroenteritis developed after 7 days of treatment with cholestyramine, and resulted in therapy being stopped. | One subject stopped cholestyramine therapy due to febrile gastroenteritis.
| | Lipid clinic, Johns Hopkins Hospital | | | The pattern of inheritance of hyperlipidemia was not indicative of familial combined hyperlipidemia in any of these kindreds; none of the affected members had type-III hyperlipoproteinemia. Secondary causes of hyperlipoproteinemia were excluded in each patient by tests of thyroid, renal, and liver function. | | | Average cholesterol intake was 159 mg/day (range 118–200) with mean ratio of polyunsaturated to saturated fats of 2.1 (range 1.9 to 2.2). Thirteen patients were given cholestyramine, with dose increased by 1 g daily until a total dose of 16 g/day was achieved. Mean dose of cholestyramine = 11 g/day. | Mean serum-folate among 15 patients before treatment was 9.0 ng/mL, and did not differ significantly between males (mean 9.8 ng/mL, N=5) and females (mean 8.6, N=10). Serum folate was measured after treatment in 11 patients. Analysis by sex showed an upward trend for 4 males but a significant decrease in serum-folate in 7 females.
| | | | | | | | | SGOT increased in 2 patients (by 32 and 41 i.u./L). Two other patients had significant increases in LDH (>70 I.U./L). These results were not accompanied by any significant changes in other tests of hepatic function. The increases in SGOT persisted for 6 months then became normal. Increases in LDH were only transient. No other abnormal chemical measurements were observed.
Glueck, 1973 ^263^ | Pediatric familial type II hyperlipoproteinemia: therapy with diet and cholestyramine resin | Noncomparative clinical study | To evaluate the effects of diet and diet plus cholestyramine on cholesterol and LDL in 36 children with familial type II hyperlipoproteinemia from 18 kindreds with documented familial type II. | 6 months with additional 12–18 months follow-up for growth | 36 children aged 7–21 from 18 kindreds with well-documented familial type II hyperlipoproteinemia were studied. These children had been originally found to b e heterozygous for familial type II hyperlipoproteinemia. Excluded secondary hypercholesterolemia. | 36, including 20 on diet plus cholestyramine | Age 7–21 | Children and their parents were instructed to ingest a low cholesterol type II diet (<300 mg/day), and were seen monthly thereafter. At monthly visit, diet adherence was reviewed with a written 24-hr diet recall, separately with the children and their mothers. After 6 months of diet, the children were arbitrarily separated into two groups, diet responders (n=11, LDL < 170 mg/dl) and diet non-responders (n=25, LDL 170+ mg/dl). | 10 of 12 routinely took the suggested dose of cholestyramine. | Of the 20 children on cholestyramine, 10 routinely took the suggested dose and also adhered to diet. 10 others had good diet adherencew but did not consistently take the full cholestyramine dose.
| | | | | | | | 20 of the diet non-responders then received cholestyramine therapy (12 g/day) in addition to diet, and were seen monthly with review of adherence. | Weight gain and growth progressed during the 12 and 18 month follow-up period along normal gwoth percentile. No consistent changes in any of the laboratory safety tests (CBC, liver function tests, BUN, calcium, phosphorous, total prtein, electrolytes and carbon dioxide).
| | | | | | | | Safety measures at monthly visits included height, weight, blood pressure, physical exam, drug and diet adherence. Lab tests were obtained at every other visit, including full hemogram, liver function tests, blood urea nitrogen, calcium, phosphorous, total protein (albumin/globulin), electrolytes, and carbon dioxide. | No evidence for hypercholoremic acidosis at any time.
Glueck, 1974 ^262^ | Plasma vitamin A and E levels in children with familial type II hyperlipoproteinemia during therapy with diet and cholestyamine resin | Noncomparative clinical study | To evalute the short-term effectgs of diet and diet plus cholestyramine on plasma vitamin A and E levels in 46 children with familial type II hyperlipoproteinemia, and in 36 normal children. | average follow-up of 6 months | Diagnoses of hypercholesterolemia and hyperbetalipoproteinemia were made in 46 children, aged 5–21, from 19 kindreds with famlial type II hyperlipoproteinemia. These children were heterozygous for familial type II and the primary nature of their hyperbetalipoproteinemia was confirmed by exclusion of common diosrders which produce secondary hypercholesterolemia. 36 normocholesterolemic siblings of the hypercholesterolemic children were also studied. | 46; of whom 30 were on diet plus BABR | Age 5–21 | Children were instructed to ingest a low cholesterol Type II diet. Diets were not supplemented with adidtional vitamins A, D, K, or E. Diet adherence was reviewed at monthly visits. The 46 hypercholesterolemi children were maintained on the diet for an average of 4 months per child, then divided into two groups: 16 whose TC & LDL normalized, and 30 whose TC and LDL did not normalize on diet. These 30 were then placed on cholestyramine in addition to the diet (12 g/day) and seen at monthly intervals, with average followup of 6 months on diet and cholestyramine. | Plasma vitamins A and E remained within the normal range and paralleled at higher levels the 25th to 75th percentile distirbution for vitamin A and E in normal children. | NR
Glueck, 1977 ^260^ | Therapy of familial hypercholesterolemia in childhood: diet and cholestyramine resin for 24 to 36 months | Noncomparative clinical study | To determine whether a higher dose of cholestyramine (16 mg/day) would provide a more substantial cholesterol level-lowering effect. | 16 children followed for 18 months; 12 for 24 months; 7 for 30 –36 months | Sixteen children heterozygous for familial hypercholesterolemia (aged 9–17) from six kindreds with well-documented familial hypercholesterolemia were studied. Their ascertainment, the nature of their hypercholesterolemia, their response to diet, and their short-term response to cholestyramine resin (12g/day) have been previously described. (see Glueck, 1973) | 16 (same children as in Glueck 1973 above, who were on diet plus cholestyramine) | Age 9–17 | In this study, at month 13 of the 6-month Glueck 1973 study, the dose of cholestyramine was increased to 16 g/day and the children were followed up subsequently for an additional 1–2 years. The children were seen in the outpatient research clinic every 4–6 weeks. At each visit, adherence was reviwed using 24-hour diet recall. Drug adherence was determined by packet count. Assessment of AES included clinical symptoms and questions about constipation, nausea, flatulence, overall palatability of the resin, and fatigue. 16 children were followed up for months 13–18, 12 for months 19–24, 7 for 25–30, and 31–36. | 1 child had persistent consitipation. None had nausea. 5 complained that resin was gritty, had poor palatability. 1 complained of chronic fatigue. CBC, liver function tests, vitamin A and E, calcium, phsophorus, blook urea nitrogen, fasting blood sugar levels did not vary signficantly over time when compared to baseline levels on diet only. | 11 of 16 had good adherence. 5 children dropped out after 2 years because of poor palatability of the drug.
Glueck, 1986 ^261^ | Safety and efficacy of long-term diet and diet plus bile acid-binding resin cholesterol lowering therapy in 73 chlidren heterozygous for familial hypercholesterolemia | Observational study | To examine the safety and efficacy of long-term diet and diet plus BABR therapy for pediatric familial hypercholesterolemia in 73 children heterozygous for familial hypercholesterolemia | 4.3 years | The 73 children were heterozygous for familial hypercholesterolemia as defined by primary elevations of total and/or low-density lipoprotein cholesterol equal to or more than the age, sex, and race-specific 95th percentile, absence of secondary causes of hypercholesterolemia, and at least 2 similarly affected first degree relatives. | 73, including 33 on diet plus resin therapy | mean age 10.3 | 73 children heterozygous for familial hypercholesterolemia were compared with 39 normal healthy children wfrom a local pediatric practice, matched for sex and age at entry, who were ingesting habitual diets without modifications by family or physicians. Height and weight were obtained in both groups of children. | Height and weight percentiles at completeion were no unchanged from baseline. No abnormal growth patterns noted. Sexual maturation was normal. None had unusual infections or extra school sick days. None of the girls had ammenorrhea; though 1 competitive cross-country runner had persistently irregular periods. No depression, suicide attempts or traumatic deaths. | 4 children exhibited transient refusal to follow diets and/or take bil acid-binding resins.
| | | | | | | | HeFH children were put on a modified type II diet. Dietary adherence was assessed at each visit. BABR therapy (cholestyramine or colestipol, 8 to 20 g/day) was not started until the children had been on diets alone for at least 4 months.
| | | | | | | | No hypocaloric regimens were recommended, and supplemental fat-soluble vitamins were not given. Serum folic acid levels were not systematically measured.
Groot, 1983 ^248^ | The effects of colestipol hydrochloride on serum lipoprotein lipid and apolipoprotein B and A-1 concentrations in children heterozygous for familial hypercholesterolemia | Non-randomized, cross-over placebo controlled. | To evaluate the effects of colestipol vs. placebo on serum lipoprotein lipid concentrations in heterozygous hypercholesterolemic patients consuming a type II-A diet | 16 weeks | Inclusion criteria:; 1 One parent with hypercholesterolemia or who had died from cardiovascular disease.; 2 Serum cholesterol levels >6.2 mmol/l and serum triglycerides normal (<1.5 mmol/L) after a low fat breakfast.; 3 No disease associated with secondary hyperlipidemia; no hypertension. | 33 children | Not given | Placebo was silicagel stained with FeCl3. Dose of colestripol or placebo was 5 g at AM and 5 gm at dinner for children <40 kg; and 10 gm at breakfast and 5 gm at dinner for children >40kg. | NR | 5 children withdrew because they didn't like the taste of the medication: 2 in the group that started with colestipol and 3 in the group that started with placebo.
| | in children ages 7–15 with heterozygous familial hypercholesterolemia type II-A | | | | Two comparable groups were formed with respect to age, sex and serum cholesterol concentration. | | Mean dose was 0.34+0.08 (mean+sd) g/kg/body weight/day.
| | The Netherlands | | | | One group given placebo then colestipol (8 weeks of each); the other group given colestipol then placebo.
Hansen, 1992 ^249^ | Growth during treatment of familial hypercholesterolemia | Descriptive study | To observe somatic growth in children treated for FH. | 8.5 years in 13 (diet); 5.5 years in 17 patients (diet followed by diet + colestipol) | Children with FH were followed in a pediatric lipid clinic for at least one year from 1970-1987. Several children were ascertained through a neonatal pilot screening program. The diagnosis of FH was based on increased concentrations of serum total and low-density lipoprotein cholesterol in the child, in one of the parents and in other members of a pedigree compatible with autosomal dominant inheritance of type IIa hyperlipidemia. Secondary hyperlipidemia was excluded by obtaining normal results on laboratory tests of thyroid, renal, hepatic, and glucose metabolism. | 30 | Age range 1/17, median 4.5 | Dietary counseling was provided by the physician in the lipid clinic. 17 children additionally received colestipol at 125–250 mg/kg/day in 1–2 daily doses. | Among all 30 children, the SD scores for both height/age and weight/age decreased by approximately 0.4 during dietary treatment (p<0.05), but were not affected by treatment with colestipol. The addition of colestipol to the dietary regimen of 17 children did not cause any statistically significant change of growth. No child decreased to below -2 SD during dietary treatment. During treatment with colestipol the height/age, but not the weight/age, of only one child decreased below -2 SD. A deficit of 0.4 SD score for a 10-year-old boy corresponds to approximately 1.8 kg in weight and 2.4 cm in height. | NR
| | Pediatric lipid clinic, Denmark | | | | | 53% female
Harvengt, 1976 ^250^ | Colestipol in familial type II hyperlipoproteinemia: a three-year trial | Non-randomized, single-blind trial with placebo lead-in phase | To evaluate the effects of colestipol on serum cholesterol in patients with primary type II hyperlipoproteinemia. | Up to 36 months of treatment, following 6-wk placebo | Inclusion criteria: | Included 3 children: ages 6, 11, and 18 | 3 pediatric patients: | All patients followed a diet less than 300 mg cholesterol daily with polyunsaturated-saturated fatty acid ratio >1,8. Patients were given an inert cellulose powder as placebo for 6 weeks. | There were only 3 children in this study, and no AEs were observed in them except for low iron level without anemia was seen in an 18-yr-old female. No hepatic dysfunction, renal function, or hematologic side effects were observed. The prothrombin time values were not abnormally prolonged during colestipol medication. Fasting blood sugar increased from 74 mg/dl (placebo) to 88.5 mg/dl after 18 months of treatment, but returned to baseline values after 3 years. Serum uric acid level increased during treatment but did not reach abnormal values. There was no steatorrhea in patients receiving colestipol. | NR
| | 13 patients aged 6 to 61 with familial type II hyperlipoproteinemia | | | Hypercholesterolemia or tendon xanthomas or both. Type II lipoproteinemia was defined by serum cholesterol and triglyceride levels, agarose lipoprotein electrophoresis pattern, clinical signs (corneal arcus, xanthomas), and familial study. | | 1 male aged 6 | Colestipol was then given before meals in 5 gm t.i.d. | Serum vitamin B12 and folic acid content were not impaired after 2 and 3 years on colestipol. Serum iron concentration was low in one pediatric patient, without hematologic signs of anemia. “There was some increase in weight in the two children.”
| | | | | | | 2 females age, 11 and 18 | | Mild gastrointestinal complaints (flatulence, constipation) were described during the first 3 months of treatment, which disappeared despite continuation of treatment.
Koletzko, 1992 ^251^ | Treatment of hypercholesterolemia in children and adolescents | Descriptive study, lipid clinic, Germany | To study the effects of outpatient treatment with diet alone or with combined diet and drug therapy in pediatric outpatients. With genetic hypercholesterolemia. | Diet: 4–70 months (mean 17.5 months) | Diagnosis of primary genetic hypercholesterolemia was based on a positive family history suggestive of dominant inheritance and on at least two fasting blood tests with results for total cholesterol, LDL cholesterol, and in the case of familial combined hyperlipidemia, triglycerides also, exceeding the 95th percentile for age and sex as well as a positive result of lipoprotein electrophoresis. | 35 on diet only | Mean age 7.9 (range 2–17.6) | Diet focused on limiting intake of saturated fatty acids to ≤10% of energy and replacing them with poly- and monounsaturated. Fats as well as reducing cholesterol intake to ≤100 mg/1000kcal. 14 patients, whose serum TC and LDL remained severely increased despite diet, additionally received cholestyramine 2–4 times daily (mean daily dose 0.36 g/kg) in addition to continued diet therapy. | No serious side effects were noted with both forms of treatment (diet/ diet + BABR). “Mild gastrointestinal symptoms occurred in very few patients.” Percentile values for weight and length remained unchanged in all patients with the exception of three overweight children whose weight fell by more than 5 percentage points but remained above the 50th percentile. | NR
| | | | Combined therapy, mean observation period was 27.9 months | | 14 on diet + BABR
Liacouras, 1993 ^252^ | Use of cholestyramine in the treatment of children with familial combined hyperlipidemia | Observational | To report the experience with cholestyramine in children over a 10 year period. | Varied, 0–62 months | Referred to Lipid Heart Clinic at Children's Hospital of Philadelphia (87 of 673 children referred met criteria) | 87 | 85 met criteria for HeFH (n=36) or FCHL (n=51). 2 others were included because of family history; thus 87 children were treated with cholestyramine. | All children had failed diet alone. | Of the 62 who continued more than 1 month on the drug, 15 had an adverse effect: | 73% complained of poor palatability | Unclear duration of treatment; post treatment values represent lipoprotein profiles taken at the time of maximum decrease of LDL (6–12 months).
| | Philadelphia | | | Heterozygous FH (HeFH) was diagnosed if the plasma LDL-cholesterol level was above the 98th percentile in both the child and an affected parent and if total cholesterol levels were greater than 300 mg/dL in another 1st degree family member. | | FCHL group: Average age 10.4+3.9 years; male/female ratio 18/19 | All continued to adhere to a Step 1 NCEP diet. | 12 nausea, 2 abdominal bloating, 1 severe constipation. | After cholestyramine therapy was initiated 7 pts (8%) failed to return for follow-up visits, 18 (21%) began medication but discontinued it within 1 months, | No intention-to-treat analysis
| | Lipid clinic | | | Familial combined hyperlipidemia (FCHL) was diagnosed when both the child and an affected parent had a plasma LDL-cholesterol or triglyceride level above the 90th percentile and a first degree relative had documented hyperlipidemia and at least one affected family member had a plasma triglyceride value >90th percentile. | | HeFH group: average age 10.7+4.3 years; male/female ratio 13/12. | Cholestyramine given as Questran, initially as 4 gm/day in 2 divided doses; then increased in increments of 4 gm/day every 8–12 weeks up to 16 gm/day unless LDL levels dropped to <130 mg/dL or side effects occurred. In four patients the dose was increased to greater than 16 gm/day. | 73% complained of poor palatability | 62 (71%) continued to take medication >1 months and complete f/u visits
| | | | | Exceptions: 2 children were included in the study because of a strong family history of premature heart disease. | | | All patients were given a multivitamin at hospital. | No instances of elevated prothrombin times.
McCrindle, 1997 ^74^ | Acceptability and compliance with two forms of cholestyramine in the treatment of hypercholesterolemia in children: A randomized, crossover trial | Randomized crossover | To compare acceptability, compliance and effectiveness of two forms of cholestyramine resin in treatment of hypercholesterolemia in children. | 28 weeks | 1 Age 10 – 18 years; 2 1 or more parent with heterozygous familial hypercholesterolemia type IIA or IIB; 3 Fasting serum LDL of 130 mg/dl or more while on American Heart Association step 2 diet; 3 No contraindications to use of cholestyramine; 4 No lipid-lowering agents other than those in study protocol | 40 | 43% female | 6 week washout period followed by random assignment in pairs to either 8 gm/day of cholestyramine powder (4 gm packets) or pills (1 gm tablets) for an 8 week period. Drug dispensed with random over count, and subjects instructed to return unused drug at end of drug period. Subject completed log book during the 1st week on amount of drug taken, acceptability and adverse effects, with questionnaire at weeks 4 and 8. After the first 8 week course of medication and assessment, there was another 6 week wash-out, followed by crossover to the alternate form of medication and assessment. | 38/40 (95%) completed both medication periods | At end of study, 82% preferred pill, 16% powder, and 2% neither form. Mean (+/-SD) compliance as assessed by amount of medication taken was greater for pills (61% +/-31% than powder (50% +/- 30%, p=0.01). Form of medication increased compliance by at least 25% for 16 patients (42%), 13 in favor of pills and 3 of powder. | No control group
| | Patients recruited from 2 lipid disorder clinics | | | | | 2 siblings from 6 families | | Authors noted minor gastrointestinal complaints were frequent but did not result in any drop-out | | Small sample size
| | | | | | | 3 siblings from 1 family | | | | At baseline, pill group had perception of increased importance of diet
| | | | | | | Median age at enrollment: 13 (10–18)
| | | | | | | Median age at diagnosis: 9.5 (0.1–17.2)
McCrindle, 2002 ^75^ | A Randomized Crossover Trial of Combination Pharmacologic Therapy in Children with Familial Hyperlipidemia. | Randomized cross-over trial | To determine the short-term safety and effectiveness of combination drug therapy in children | 18 weeks each period | 1 Children between ages 8–18; 2 Positive family history of hypercholesterolemia or premature atherosclerotic cardiovascular disease in first-degree relatives; 3 Minimum fasting LDL cholesterol level before enrollment >4.15 mM/L; 4 Participation and compliance in dietary counseling program for at least 6 months.; 5 No secondary cause for hyperlipidemia, no major surgery or serious illness within past 3 months. | 40 randomized to either colestipol 10g/day alone or colestipol 5 g/day +pravastatin 10 mg/day | 11 girls, 25 boys median age 14, range 9–18 | colestipol 10g/day (10 tablets) alone vs. colestipol 5 g/day (5 tablets) plus pravastatin 10 mg/day (1 tablet) for first 18 week period, followed by 8 week wash-out period and then each group crossed over to the other treatment for the second 18 week period. | Symptoms reported at the end of the study in the final preference questionnaire showed that the majority of patients had no symptoms. 18% reported constipation with colestipol vs. 0% with the combination vs. 3% who had it with both, 12% reported bloating/gas with colestipol alone vs. 0% with combination (3% had it with both). 21% had stomach ache with colestipol alone vs. 0% with combination vs. 0% with both. 11% had headache with colestipol vs. 0% with combination vs. 3% with both regimens. 6% had muscle aches on colestipol along vs. 3% with combination vs. 0% with both regimens | Compliance was 57–66% overall and was similar between treatment groups and dose groups. There was a decrease in compliance between the first 8-week and second (10-week) dispensing periods, this difference was not significant.
| | Lipid clinic, Toronto, Canada | | | | | BMI 22–25 kg/m2
Schwarz, 1980 ^253^ | Fat-soluble vitamin concentrations in hypercholesterolemic children treated with colestipol | Pre/post Longitudinal | To determine whether long-term administration of colestipol hydrochloride to hypercholesterolemic children along with a diet low in cholesterol is effective in reducing plasma total and LDL, and to learn if changes in plasma concentrations of vitamins A, D, E, K or folic acid occur during therapy. Also assessed effect of drug on calcium metabolism by sequential determination of serum total and ionized calcium, phosphorus, alkaline phosphatase, and parathyroid hormone. | Up to 24 months | 1 Hypercholesterolemic (values > 95th percentile for age) children aged 5 – 17; 2 Plasma triglycerides normal; 3 One or more 1st degree relative with type II hyperlipoproteinemia (1 exception); 4 Secondary causes of elevated plasma concentrations eliminated; 5 Cholesterol-lowering medications discontinued at least 3 months prior to study start; 6 No supplemental vitamins or cholesterol drugs during study (except study drug) | 23 | Hypercholesterolemic | Child and parents instructed in NIH type IIA diet, and adherence was reviewed at each visit by 24-hour dietary recall. Subjects had 2 – 8 months (average 3.6) of diet only therapy, after which those with cholesterol concentrations > 90th percentile for age were given colestipol 15 – 20 gm/day. Drug therapy up to 24 months in duration. Office visits every 2 months for diet and drug adherence checks and determination of total cholesterol and triglyceride levels in plasma. Blood work and physical exam performed twice during diet only period and at 6 monthly intervals during colestipol therapy. | No severe side effects reported. | 6 subjects complained of poor palatability of drug, and 4 withdrew for this reason. | Many uncontrolled variables: 10 patients had been on low cholesterol diets 1 – 4 years prior to study start. Range of “diet alone” treatment was 2 to 8 months, with an average of 3.6 months. Drug compliance in the good adherence group (n=13) was 82% (range 100% – 63%), and was undetermined in the poor adherence group. Poor adherence group attended 66% of visits. Only 7 patients (30%) completed 18–24 months of drug.
| | Outpatient clinic of Washington University | | | | | children aged 5 to 17 years | Measures:; 1 24 hour dietary recall; 2 Package count of unused drug on > 3 separate visits; 3 Detailed blood work: blood count, serum gluclose, urea nitrogen, glutaminic oxaloacetic transaminase, bilirubin, total and ionized calcium, phosphatase, parathormone, vitamin A, 25-hydroxycholecalciferol, prothrombin time, vitamin E, folic acid, and plasma lipid and lipoprotein quantification.; 4 Complete urinalysis; 5 Vitamin E analyzed by colorimetric assay in 1st part of study and microfluorometric assay in 2nd part.; 6 Folic acid analyzed by Lactobacillus casei method in 1st part of study and later by radioimmunoassay. (Values converted) | 1 patient developed Reynauld's phenomenon on 4 separate occasions during therapy but continued to take drug without recurrence of symptoms. | Only 7 patients completed 18 – 24 months of drug (30%); 3 controls completed this treatment segment | Both folic acid and vitamin E were analyzed by different lab methods in different parts of the study. Results section confusing. Design included 4 sibling controls with no resulting data analysis on this group. No separate analysis or adjustment for the 1 subject who did not have a 1st degree relative with hyperlipoproteinemia.
| | Lipid Research Center from 1973 to 1978. | | | | | (mean 12.2) and 4 sibling controls
| | | | | | | 35% female
Tonstad, 1996 ^254^ | Colestipol tablets in adolescents with familial hypercholesterolemia | Observational | To examine the palatability and side effects of colestipol tablets in adolescents with FH and report changes in lipid levels | 6 months for colestipol; 2–10 (mean 6) years for diet | heFH attending a referral lipid clinic; none were siblings. | 27 children | 23 boys and 4 girls ages 10–16 | All patients had previously been instructed to follow a diet restricted in saturated fat and cholesterol (<10% of caloric intake and <200 mg/day respectively). | All showed normal growth and development according to standard height, weight and pubertal staging charts over the 2–10 years that they had been followed prior to this study (on diet alone). | All preferred the tablets to granules formulations of resins. 7 people did not complete 6 month labs (or at least are not reported). In SE table, 4 people noted to have stopped med prior to 6 months; reasons include unpalatable in all cases.
| | Oslo, Norway | | | | | | All had previously taken colestipol granules or cholestyramine or both; all but 4 had stopped taking granules, usually because of unpalatability. | Two girls taking 4 tablets daily had difficulty swallowing the tablets.
| | | | | | | | Colestipol was given as 2–12 g daily usually 6 g. Doses higher than 6gm/day were divided. | One boy taking 6 tablets had abdominal discomfort at bedtime 2–3 times/week - he was taken off the med.
| | | | | | | | | 1 subject had difficulty with flatulence and swallowing the tablets.
| | | | | | | | | 24/27 reported that they forgot tablets 1–2 times/week or less.
Tonstad, 1996 ^80^ | “Low dose colestipol in adolescents with familial hypercholesterolemia” | DB RCT of colestipol 10g qd or 5g bid vs placebo | Effectiveness of colestipol in treating FH. | 52 weeks | adolescents age 10–16 referred to lipid clinic; all had two or more TC >6.2mmol/l and TG<3.0 mmol/l. | 74 targeted, 66 agreed to participate | 37 boys (58%); 29 girls mean age 13.2 | All subjects instructed to follow a diet: 30% calories from fat; <10% from saturated fat and <200 mg cholesterol/day. | Total of 7 subjects dropped out 4 in colestipol; 3 in placebo. 5 pts dropped out because they refused to swallow the drug; 2 dropped out because they had unexpectedly low lipid concentrations at randomization. | Compliance was 68% in colestipol group vs 76% in placebo group NS. | placebo group was older and more advanced tanner stage (p<0.05)
| | 67 adolescents | | | | | Tanner stage 2.6 | Assessed with 4 day weighed food record. | 8 girls did not agree to continue in the open phase. | Only one third of adolescents adhered to the drug regimen in the course of one year.
| | Norway | | | | | | Subjects randomized to drug treatment got either colestipol 10g qd or 5g bid × 8 weeks. | Of 51 in open phase, 42 completed 1 year. | Obstacles included vacations, special occasions, and unpalatability.
| | | | | | | | Open label trial after 8weeks in which placebo group started colestipol for 52 weeks; colestipol group continued on colestipol. | 8 subjects in colestipol group had GI side effects attributed to the drug: 2 had constipation that improved with temporary dose reduction; 1 had dyspepsia and 1 had flatulence throughout entire study; 2 had intermittent nausea, 1 had temporary decrease in appetite; 1 had abdominal pain improved with dose reduction.
| | | | | | | | | Linear growth velocity was within reference range for Norwegian adolescents. 1 pt lost >1 kg during the study (24.5 kg/m2 pre and 21.3 kg/m2 post).
| | | | | | | | | Lab values: Low-dose colestipol (10 g/day) reduced concentrations of serum folate after 8 weeks. Serum vitamin E and carotenoids decreased proportionally with decreases in cholesterol. Vitamin D did not change significantly, but decreased more in subjects who were more compliant after 1 year.
Tonstad, 1996 ^81^ | Efficacy and safety of cholestyramine therapy in peripubertal and prepubertal children with familial hypercholesterolemia | Random assignment to double-blind comparison | To determine the efficacy and safety of cholestyramine therapy in young children with familial hypercholesterolemia | 1 year | 1 Familial hypercholesterolemia diagnosed if TC > 260 mg/dl and triglyceride levels < 200 dl, if 1 parent had baseline cholesterol > 300 mg/dl and triglyceride levels < 200 mg/dl, or tendon xanthoma, or if autosomal dominant inheritance present in other members.; 2 Prepubertal girls aged 6 – 10, and prepubertal boys aged 6 – 11 who completed an initial medical evaluation and dietary session and had a parent who understood the diet.; 4 Height velocity score standard deviation score > -2.0.; 3 Those taking lipid-lowering drugs were required to discontinue doing so at least 4 weeks before study start; 4 Secondary hyperlipidemia ruled out by clinical and lab examination. | 96 randomized, 36 to drug | Drug group | After 1 year of a low-fat, low-cholesterol diet, children with LDL > 190 mg/dl or > 160 mg/dl in the presence of familial premature cardiovascular disease were randomly assigned to a double-blind comparison of 8 gm cholestyramine or placebo for 1 year. | In the drug group, folate deficiency occurred in one subject, in whom the total homocysteine level increased concurrently. With the exception of modest decreases in levels of vitamin D during the winter, other nutritional deficiencies were not observed. | 22 of 36 completed 1 year of cholestyramine, having taken 77% of all doses, and 26 of 36 on placebo completed 1 year, having taken 83% of all doses (ns). | 1 High attrition: only 22/36 (61%) in drug group and 26/36 (72%) in placebo completed the study.; 2 Only about half the children were able to take cholestyramine in the amount prescribed, primarily because of unpalatability.
| | Norway | | | | 36 to placebo | Mean age: NR | Dieticians reinforced the diet at each visit. Dietary composition assessed by a 7 day record, evaluated by FIBER. Assigned dose 8 gm/day, following 1 week build-up phase of 4 gm/day. Follow-up visits scheduled after 2, 5, 7, 9 and 12 months. Compliance assessed by counting leftover packages at each visit. | No adverse effects on growth and bone age evident. No difference in mean height velocity standard deviation scores in those who hadn't started puberty. There was one case of intestinal obstruction caused by adhesions | 12 of 14 withdrew on cholestyramine due to unpalatability within 2 months, as did 9 of 10 on placebo.
| | Boys aged 6 to 11 years and girls aged 6 to 10 years with familial hypercholesterolemia in a referral lipid clinic | | | | | Female gender: 44% | | One on cholestyramine vomited after taking 2 packets, and withdrew.
| | | | | | | Race: NR | | One on placebo reported vomiting for 3 weeks and withdrew. Another on cholestyramine reported more frequent headaches and withdrew.
| | | | | | | Placebo group
| | | | | | | Mean age: NR
| | | | | | | Female gender: 33%
| | | | | | | Race: NR
Tonstad, 1998 ^255^ (See Tonstad 1996 ^81^ ) | The C677T mutation in the methylenetetrahydrofolate reductase gene predisposes to hyperhomocysteinemia in children with familial hypercholesterolemia treated with cholestyramine | Placebo-controlled RCT; lipid clinic, Norway | To investigate whether the elevation of plasma total homocysteine observed during cholestyramine treatment was related to the methylenetetrahydrofolate reductase genotype in children with FH. Cholestyramine may increase tHcy by inhibiting the absorption of folate. | 1 year | Subjects were boys and girls aged 6 to 11 with FH who had participated in a 1-year open study of Step 1 diet. | 96 | Mean age 7.98 | Children were randomized to 8 g/day of cholestyramine or matching placebo granules for 1 year. | During cholestyramine treatment, tHcy concentrated increased in subjects with the C677T mutation in one or both alleles but not in subjects with the CC genotype. In contrast, there was a reduction in serum folate in most subjects, regardless of genotype. | 22 (61%) of 36 in the cholestyramine group, and 26 (72%) of 36 in the placebo group completed 1 year. Dropouts were usually due to unpalatability of the drug.
| | | | | | | 40% female | Blood was collected at baseline and 1-year follow-up, and analyzed for plasma tHcy, serum folate, and MTFHR status. | In the placebo group, tHcy and folate showed no consistent changes.
| | | | | | | | Serum folate was measured by radio assay.
West, 1973 ^256^ | Use of cholestyramine in the treatment of children with familial hypercholesterolemia | Descriptive study | To report the experience in the treatment of 19 children with HeFH using cholestyramine. | Up to 20 months | Most children were referred because of a family history of early onset of ischemic heart disease. All were asymptomatic but one 13-year-old boy was detected because of skin xanthomata behind the knees, and one 9-year-old girl had corneal arcus. All patients had characteristic biochemical evidence of familial hypercholesterolemia (i.e. raised TC and normal fasting TG, with increased B-lipoprotein by electrophoresis and density gradient ultracentrifugation). Also, at least one of the parents had the same lipoprotein abnormality or had died of ischemic heart disease. | 19 children from 11 families | 38.7% female | Cholestyramine twice daily in a total dosage of 8 to 24 g/day (0.3 to 1.1 g/kg body weight per day). In 11 patients cholestyramine therapy was combined with a diet low in saturated fat (<20 g daily) and containing some supplementary corn oil and corn oil products. 8 patients remained on a normal diet during cholestyramine therapy. In 4 patients a comparison of twice-daily therapy with 4-times daily was made, starting with a dose of 4 g 4 times daily before food, followed by 8 g twice daily (total dose unaltered). | Absorption of fat was impaired in some patients but has not been associated with diarrhea. Fecal fat was estimated in 9 patients receiving cholestyramine. 5 of 7 children on a normal fat intake had steatorrhea with mean fecal fat ranging from 5.3 to 10.5 g/day. Serum folate levels decreased in all patients, and 6 of 12 tested had subnormal red blood cell folate. There has been no evidence of malabsorption of other vitamins or of minerals. Growth rate has been normal in all children. | NR
| | | | | | | | | In all patients, growth and height and weight continued along the pretreatment centiles, with no change in velocity. None developed anemia, and hemoglobin, prothrombin time, serum calcium, alkaline phosphatase, and serum vitamin A concentrations have remained unchanged.
West, 1975 ^257^ | The effect of cholestyramine on intestinal absorption | Descriptive study | To monitor the effect of long-term treatment on the absorption of fat, vitamins, and some minerals among children with FH treated with cholestyramine. | 1 to 2.5 years | Children with the HeFH. IN the majority there was a history of premature ischemic heart disease in a near relative. None of the children had any evidence of heart disease, two had corneal arcus, and one had skin xanthomata and was also overweight. | 18 | Age 1–14 years | Subjects were treated with Questran brand cholestyramine. For 16 children, treatment was given twice daily in a dose of 0.2 to 1.1 (mean 0.6) g/kg/day. Two children took an equivalent dose 3 times daily. Eight children remained on their normal diet, and 10 were initially given a diet low in saturated fats supplemented with corn oil and corn oil products. No patient received vitamin or mineral supplements. For most patients, hemoglobin, prothrombin time, plasma calcium, phosphorus, protein, and alkaline phosphatase, serum folate, iron, and vitamins B12, A, and E were estimated in the majority before treatment and at 3 month intervals thereafter. Red blood cell folate was not determined at baseline was later added to the investigations. | With prolonged treatment, folate deficiency occurred: mean serum folate decreased from 7.7 ng/ml pre-treatment to 4.4 ng/mL for patients on treatment for over 1 year; a corresponding lowering of red cell folate also occurred. Oral folic acid 5 mg daily overcame this depletion. Prothrombin time remained normal in all patients. There was a significant decrease in mean serum levels of vitamins A and E and of inorganic phosphorus over the first 2 years of treatment, although values remain within the normal range. In children on a normal intake of dietary fat, five of 7 tested had fecal fat >5g/day while on cholestyramine. No child developed diarrhea, and growth has been normal. Levels of serum iron, vitamin B12, plasma calcium, and protein did not change significantly. | NR
| | UK
West, 1975 ^258^ | Treatment of children with familial hypercholesterolemia | Observational | To report the results of three different treatment regimens used to control cholesterol in children with heterozygous familial hypercholesterolemia (familial type II hyperlipoproteinemia) over an 8 year period. | Varied, 2–8 years | 45 children with diagnosis made as the result of a family study of serum lipoproteins carried out because of premature coronary heart disease in a near relative (often a parent); diagnosis confirmed by identification of the lipoprotein abnormality in a t least one other first degree relative. | 45 children | 23 boys, 22 girls ages 1–16 | Three different regimens:; 1 Diet modification alone (17 children): Diet consisted of a reduction in ordinary fat intake to about 18 g/day, and use of corn oil.; 2 Dietary modification with clofibrate (9 children): clofibrate was administered 18–28 mg/kg/day; diet same as that above. All of these children failed diet alone before starting clofibrate.; 3 Cholestyramine (36 children): given as Questran in a total daily dose of 0.3–1.1 g/kg/day given in two equal divide doses in most children. Initially, low saturated fat diet was given with cholestyramine but then changed to allow most children to consume a reasonably normal diet. | Diet: lack of compliance | Diet: By the end of 18 months, only 20% of the group were either satisfactorily maintained (at a cholesterol 10% lower than baseline). | Poor - can't tell really who got what, for how long, or which children switched regimens.
| | London | | | | | | Several children were managed sequentially be more than one regime. | Clofibrate: intolerance of drug | Clofibrate: By 2–1/2 years, no child was still on the drug (stopped on their own, or stopped because of inadequate cholesterol lowering).
| | | | | | | | | No obvious short-term side effects were apparent with diet alone, or diet and clofibrate, but adherence to these regimens was poor. The growth rates of the 3 children maintained on diet alone have been normal. | Cholestyramine: A few children stopped the drug after a short period because they found in unpalatable. After 2 years of treatment 72% remained satisfactorily controlled and after 3 years this number was 57%.
| | | | | | | | | Cholestyramine: unpalatable in some. Side effects have included folate deficiency, steatorrhoea, and reduction in serum levels of vitamins A and E and of inorganic phosphorus although not to abnormally low values.
| | | | | | | | | (see withdrawals)
| | | | | | | | | Cholestyramine:
West, 1980 ^259^ | Long-term follow-up of children with familial hypercholesterolemia treated with cholestyramine | Observational | To assess the impact of cholestyramine in children with FH. | 1–8 years | children with FH as defined by 1) elevated plasma beta lipoprotein and cholesterol concentrations (cholesterol above 7 mmol/L or 270.7 mg/dL) in the patient, in the absence of other disease that could cause hyperlipidemia and with a first-degree relative who either had the same pioprotein disorder or who had died of IHD before age 45. | 35 children | 16 girls, 19 boys | For 8 children cholestyramine was started as initial therapy. | Almost all children expressed some dislike of cholestryamine, and a few complained of transient gastric fullness after taking a dose. No patient had persistent constipation, loss of appetite or diarrhea. No other symptoms were reported. | 2 children refused further medication after the first dose. | No intention-to-treat analysis.
| | London | | | | | ages 1.3–17.4 years (mean 8.4) | For 27 patients initial treatment had been with a low saturated fat diet— this either could not be tolerated long term or failed to lower the cholesterol levels below 6.5 mmol/L (251.3 mg/dL). | One girl (age 18.6 yrs) stopped medication after 79 months on cholestryamine because she developed nausea, dizziness and malaise. | 1 boy died of tercurrent infection
| | | | | | | 8 sibling pairs. | Cholestyramine was started at 2 g or 4 g twice daily before meals, the dose gradually increased until either the plasma-cholesterol concentration was below 250 mg/dL or until the maximum tolerated dose was being taken. | | 10 months after starting cholestryamine. Only 55% remained on treatment after 6 years; 48% after 8 years.
| | | | | | | | All patients were given 5 mg folic acid supplements daily. | | Of the 25 children under age 10 who were started on cholestryamin, 14 or 67% remained on treatment at the end of the study period as compared with 1 of the 10 (13%) of the children over age 10 (p<0.05).
Other drug therapies
Baker, 1982 ^54^ | Treatment of homozygous familial hypercholesterolemia with probucol | Open-label clinical study | To evaluate the effects of probucol in 10 HoFH patients | 15–21 months | Homozygous familial hypercholesterolemia based on presence of i) serum TC consistently > 14.3 mmol/l, ii) appearance of xanthomas in the first decade of life, and documentation in both parents of hypercholesterolemia or clinical signs indicative of the heterozygous state. | Included 7 children/adolescents aged 6, 8, 9, 11, 16, 18, 21. | 7 pediatric subjects: | All patients were kept on a low-cholesterol, low-saturated-fat diet supplemented with 30–60 ml maize oil daily for at least 3 months before starting probucol treatment. Two patients aged 8 and 9 were given probucol 250 mg bid, 8 patients were given 500 mg bid (one reduced to 375 mg dose because of nausea). | One patient developed nausea on 500 mg bid after 10 months, and the dose was reduced to 375 mg bid for 5 months; thereafter was given 500 mg/day without recurrence of nausea. No significant changes were noted in the results of endocrine, hepatic, or hematological investigations. In particular, The levels of total T1 and T4 and of free T1 and T4 did not alter. | Otherwise probucol was well tolerated. “The probucol regimen was simple, convenient, well tolerated and did not interfere with growth and development in children or adolescents.”
| | 10 HoFH patients aged 8–46, of whom 5 underwent portacaval shunt operation prior to probucol treatment. | | | | | 2 males aged 8 and 16 | | Otherwise probucol was well tolerated. “The probucol regimen was simple, convenient, well tolerated and did not interfere with growth and development in children or adolescents.”
| | | | | | | 5 females aged 6, 9, 11, 18, and 21
Becker, 1992 ^264^ | Long-term treatment of severe familial hypercholesterolemia in children: effect of sitosterol and bezafibrate | Open-label clinical study | To determine the effects of sitosterol and bezafibrate in sequence for 3-month periods, and a combination of both drugs at half-dose for 24 months, on serum lipid levels. Laboratory safety parameters, ultrasonography, and physical examination assessed side effects. | 30 months exposure to drug: | 1) family history of hypercholesterolemia and premature coronary heart disease in at least one first-degree family member; 2) age 7 or older; 3) total serum cholesterol >300 mg/dL and LDL >250 on at least 2 occasions with normal triglyceride levels after at least 3 months of strict dietary intervention; 4) unsuccessful intervention with bile acid-binding resins; 5) none of the children had phytosterolemia. | 7 children with HeFH | Mean age 8.42 | After 3-month diet that continued throughout the study, subjects received sitosterol pastils (3×2 g/d) for 3 months, followed by bezafibrate (2×200 mg/d) for 3 months, followed by sitosterol (3×1 g/d) combined with bezafibrate (200 mg/d) for 24 months. | After sitosterol: there was a slight but significant decrease in hemoglobin (-5%) and alkaline phosphatase activity (-19%). | Children and parents reported a high degree of acceptance and compliance during all treatments.
| | Germany | | 3 month diet | | | 42.9% female | Safety was assessed by routine lab tests; abdominal sonography performed every 6 months. | After bezafibrate: alkaline phosphatase remained lower and iron increased by 26%.
| | | | 3 month sitosterol | | | | | After 24 months of combined drugs: transferrin increased 20%, reaching abnormal levels in 2 patients. All other lab values remained within normal range.
| | | | 3 month bezafibrate | | | | | Decrease in appetite for 2 weeks was reported by 2 patients at the beginning of sitosterol therapy.
| | | | 24 months sitosterol plus bezafibrate | | | | | Physical exams and ultrasounds of gallbladder found no abnormalities during follow-up.
Brun, 1980 ^265^ | Effects of dextrothyroxine on the pituitary-thyroid axis in hypercholesterolemic children and goitrous adults | Descriptive | To evaluate the effects of dextrothyroxine (D-T4) on the pituitary-thyroid axis, the study measured the secretion of TSH in response to TRH in six euthyroid children with FH. Since the effects of thyroid hormones appear to be mediated by specific nuclear receptors, the binding affinity of D-T4 was also studied. | 12 weeks | FH criteria: one of the parents had tendinous xanthomas with increased levels of cholesterol in the LDL fraction. The children also had increased LDL. They were euthyroid and, due to their young age, had none of the clinical manifestations of FH except for hypercholesterolemia. | 6 | Aged 7–12 | All children were on a hypocholesterolemic diet at the time of the study. At the first visit, TRH stimulation (400 ug, iv) test was performed before and after 6 and 12 weeks of treatment with 6 mg D-T4 (choloxin). After 6 and weeks of therapy, the patient came back to the clinic for drug compliance assessment (via tablet counts), and measurements of serum T3 resin uptake and total T4 levels. | In the euthyroid hypercholesterolemic children before D-T4 treatment, the peak serum TSH response to TRH administration was normal. With D-T4 treatment, the secretion of both TSH and T3 in response to TRH was abolished. Also, an increase in the basal level of T3 was observed after treatment with D-T4. | NR
| | Canada | | | | | 33% female | | The high circulating levels of D-T4 and possibly of D-T3 after chronic administration of D-T4 may be responsible for the saturation of pituitary nuclear T3 receptors, resulting in the suppression of the TRH-induced TSH response.
Colletti, 1993 ^266^ | Niacin treatment of hypercholesterolemia in children | Retrospective review of patients from 2 lipid clinics in Vermont (1986-1990) and Boston (1980-1991) | report of efficacy of niacin as single-drug treatment for hypercholesterolemia in children; | 1–19 months, average 8.1 +5.3 months | All children had been previously treated with diet and bile-acid sequestrants and had not reached NCEP goals; | 21 children ages 4–14 years | Baseline values | Niacin as sole treatment for hypercholesterolemia; maximum daily dose was 7–98 mg/kg of body weight. | one 7-year old girl developed a febrile influenza-like illness with elevated serum aminotransferase>400 IU/L two months after starting niacin treatment but before the first post-treatment lipid measurement. | Drug discontinued in 1 pt for hepatitis; 1 for flushing; 1 for abdominal pain, 3 for vomiting; 2 for headache; 1 for elevation of serum aminotransferase, and 1 for poor compliance.
| | | | | Niacin subsequently prescribed as sole treatment; this drug selected because of poor compliance (n=2) or anticipated poor compliance (n=11) with sequenstrant therapy, low HDL (n=6) and parent preference (n=2). | | (mean+s.d.): | | Pretreatment LFT's had been normal; Niacin at 1000mg/day sustained release was considered a possible cause of hepatitis and was discontinued.
| | | | | | | TC=7.84+1.13 mmol/L | | Dose reduced if nausea occurred.
| | | | | | | (303+44 mg/dL) | | Flushing 71%
| | | | | | | LDL=6.28+1.16 mmol/L | | itching 19%
| | | | | | | (243+45 mg/dL) | | Abdominal pain 14%
| | | | | | | | | Nausea 14%
| | | | | | | | | headache 14%
| | | | | | | | | Constipation 5%
| | | | | | | | | Reversible serum aminotransferase elevations (dose related) in 6 patients; 4 with crystalline and 2 with sustained release form of niacin.
| | | | | | | | | 18 of 21 patients reported some adverse effect.
Malloy, 1978 ^73^ | Familial hypercholesterolemia in children: treatment with p-Aminosalicylic Acid | Single-blind random assignment pattern with cross-over at 6 months - drug | To determine the effect of p -aminosalicylic (PAS) on serum cholesterol and triglycerides in 3 lipoprotein classes in children and adolescents with severe familial hypercholesterolemia. | 1 year | 1 Severe familial hypercholesterolemia; 2 Consistently elevated serum cholesterol while on ≥ 4 month diet restricted in cholesterol and saturated fats; 3 No disorders known to contribute to secondary hyperlipidemia; 4 No other serious disorder; 5 No medications other than PAS; 6 One parent with proven and one other in kindred with hypercholesterolemia. | 20 enrolled | Median age: 12 years | Dietary cholesterol and saturated fats restricted 4 months prior to and throughout the study. Subjects and their parents received monthly dietary counseling. Single-blind assignment to active drug (150 mg/kg/day, up to 8 gm/day) or placebo during first 6 months. Dose adjusted monthly for change in body weight. After 6 months, the alternate agent (placebo or active drug) was given for 6 months. Composite index of compliance for each subject based on interviews, tacit drug inventories, and tests for PAS metabolites. Monthly clinic visits including clinical exam. | No indicators of drug toxicity reported, other than mild gastric irritation that remitted with oral antacid treatment. No patient had occult blood in the stool at any time. No ophthamologic or hematologic abnormalities were observed. SGOT, SGPT, alkaline phosphatase, bilirubin, and glucose levels in fasting serum were consistently within normal limits in all subjects. There were no departures from expected growth curves during the administration of the active drug. Levels of TSH in serum were within normal range and showed no tendency to rise during treatment with PAS-C. Thyroxine levels were normal in all samples. Triiodothyronine levels were normal in all but two in active drug and 1 on placebo. | Compliance was >50% for 11 subjects, <50% for 9 subjects. | Single-blind randomization
| | USA in Children aged 5 to 21 years with severe familial hypercholesterolemia | | | | | Female gender: 45% | | | | No separate control group: patients served as own controls
| | | | | | | | | | | Only 11/20 subjects were > 50% compliant
| | | | | | | | | | | LDL change evaluated for 8 subjects only
McDuffie, 2002 ^267^ | Three-month tolerability of Orlistat in adolescents with obesity-related comorbid conditions | Observational study, US | To study the safety, tolerability, and potential efficacy of orlistat in adolescents with obesity and its comorbid conditions. | 3 months | Obese white and African-American adolescents (aged 12–17) were recruited through newspaper ads and letters to local physicians for participation in a weight-loss study. Inclusion criteria: BMI > NHANES I, 95th percentile for age, sex, and race; and the presence of one obesity-related comorbidity: hypertension, type 2 diabetes or glucose intolerance, hyperinsulinemia, hyperlipidemia, hepatic steatosis, or sleep apnea. Exclusions: a major pulmonary, hepatic, cardiac, or musculoskeletal disorder, history of substance abuse or other psychiatric disorder, use of a anorexiant in the past 6 months, or weight loss in the past 2 months. | 20 adolescents | Mean age 14.6 | A registered dietitian instructed subjects and at least one parent or guardian how to follow a 500-kcal-deficit diet containing no more than 30% of calories from fat. Subjects were given orlistat (120 mg, 3 times a day with meals) as well as a multivitamin supplement. Subjects returned medication at 4-week intervals to assess adherence. Subjects participated in a 12-week comprehensive behavioral program that reinforced dietary principles, encouraged physical activity, and provided psychosocial support. | All but one subject reported two adverse effects on at least one occasion. Five of the 12 AEs queried: increased defecation, soft stools, fatty or oily stools, oily spotting on clothes, and increased flatus were reported by >50% of subjects. AEs were generally mild, limited to gastrointestinal effects related to increased fat excretion, and resolved within the first 6 weeks of treatment. | Subjects who completed treatment (85%) reported taking 80% of prescribed medication.
| | | | | | | 50% female | Subjects were queried weekly about AEs. At 3-month intervals, a clinical pharmacist interviewed subjects with a comprehensive questionnaire to identify expected and unexpected AEs. | A small but significant drop in 25-hydroxy vitamin D levels was seen at 1 month. 3 subjects required additional vitamin D supplementation despite the prescription of a daily multivitamin containing vitamin D. | Only one subject (5%) cited intolerance of adverse effects as reason for withdrawal.
| | | | | | | BMI 44.1 kg/m2 | | TSH, free thyroxine, glycosylated hemoglobin, calcium, phosphorous, magnesium, zinc, measures of iron stores did not change significantly during the study.
Stein, 1989 ^268^ | Treatment of familial hypercholesterolemia with drugs in children | Cross-sectional study/chart review | To assess plasma lipid levels in children and adolescents who were on various drug regimens and who were attending a specialized lipid treatment center. | N/A (cross-sectional study/chart review) | Clinic charts from 30 HeFH children and adolescents who had been treated with medication at the Cholesterol Treatment Center for 1 to 9 years were reviewed. | 30 HeFH children | Mean age 5.5, range 1–20 | After stabilization and maximal lipid reduction by diet, drug therapy consisted of a BABR, either colestipol or cholestyramine. Niacin treatment was added only when LDL lowering with resin alone was insufficient to decrease values below the 90th percentile. Three children with HoFH were also treated with a variety of drug combinations, usually consisting of a BABR (colestipol 15 to 30 g/day or cholestyramine 8 to 16 g/day), niacin (1 to 3 g/day), and in some cases, clofibrate. Six subjects with severe HeFH, where resin and niacin were inadequate, were entered into formal studies with an HMG CoA reductase inhibitor (lovastatin 80 mg/day or simvastatin 40 mg/day). | The combination of resin and niacin produced elevated liver enzymes (AST and ALT) and clinical symptoms of hepatotoxicity in one subject. | NR
| | Lipid clinic, US | | | | | | | Niacin in this subject was associated with a significant rise in liver enzymes, suppression of albumin, and clinical symptoms of hepatotoxicity. No adverse clinical or biochemical side effects were noted on the HMG CoA reductase inhibitor.
Steinmetz, 1981 ^269^ | Biological variations in hyperlipidemic children and adolescents treated with fenofibrate | Descriptive study | To learn how effective fenofibrate is in treating hyperlipoproteinemia and whether it has secondary effects on the biological parameters assessed in clinical laboratory tests. | 18 months | 17 patients were followed in the Diabetes Service. Most patients had hyperlipoproteinemia Type Iia; four had mixed Type-Iib. | 17 | Aged 4–19 | All were put on a low-lipid diet (cholesterol <300 mg/day). After 3–6 months of diet, fenofibrate was given at 200 mg/day, readjusting to 100 or 300 mg/day if needed. | The study found a significant and major decrease in total alkaline phosphatase activities, uric acid, and bilirubin. 4 or 17 subjects had increases in ALT activity of at least 100%, and in AST activity of at least 80%. These increases persisted as long as the treatment was maintained. A decrease was observed only if the treatment was suspended. | NR
| | France | | | | | | Fasting blood samples were collected before treatment and after 3 months, and after 6, 10, 12, 14, or 18 months in 10 patients. | Uric acid decreased significantly (mean change -20%). Bilirubin decreased significantly (mean change -19%). Inorganic phosphates decreased slightly but significantly. Albumin was unchanged. Alkaline phosphatase decreased by 15% on average. GGT activity decreased slightly (by 1.5 U/l). ALT increased by 9 U/l. AST increased by 11 U/l.
| | | | | | | | Reference values were obtained from a group of children of healthy families.
Wheeler, 1985 ^82^ | Double blind trial of bezafibrate in familial hypercholesterolemia | DB randomized cross-over trial | To evaluate the use of benafibrate for lower cholesterol in children. | 6 month crossover; 3 months on bezafibrate | Diagnosis of FH established by TC>6.7 mmol/l (269 mg/1000 ml), a type IIa pattern on lipoprotein electrophorsesis and normal fasting TG (<1.5mmol/l) in the pt; with either similar lipoprotein abnormalities in one of the parents or premature CHD death in a parent and a similar lipid abnormality in another close relative. | 14 children; all had previously been treated with dietary measures (inadequate to control cholesterol), had been recommended cholestyramine but refused to take it. | Aged 4–15 (mean 10.9) | 1 Children asked not to change their diets; 2 10–20 mg/kg/day given bid (in 100 mg tablets) given for 3 months | 1 One child had high alk phosphatase at the end of 3 months of bezafibrate (had a slight intercurrent infection, and values returned to normal); 2 Another child had slight transient rise in alanine transaminase during first 2 months on bezafibrate but values were normal by end of 3rd month; 3 growth was satisfactory throughout trial; 4 no other reports of adverse effects | In all but one case bezafibrate was detected in the urine on all measurements during the active drug phase, and in none of the measurements while on placebo. | Rated poor quality
| | | | | | | | | | All children declared a strong preference for this drug as compared with cholestyramine used previously. | No results prior to cross-over.
| | | | | | | | | | | No wash out period between cross over periods.
Low-fat diet
Cetta, 1994 ^279^ | Growth patterns of hyperlipidemic children enrolled in a preventive cardiovascular health clinic | Retrospective, descriptive study | To assess growth patterns of hyperlipidemic children enrolled in a preventive cardiovascular health clinic, by retrospective chart review. | 2 years of follow-up | Entrance criteria:; 1) hyperlipidemia (LDL ≥110 mg/dL or TG >95th percentile with a normal LDL),; 2) lack of any chronic disease,; 3) a minimum of 2 years of clinic participation. | 63 | Mean age 7.8 (range 2 to 16) | All participants were counseled to eat an AHA Step-One Diet and exercise regularly. Weight and height were measured 12, 30, and 48 weeks after the initial visit, and every 3 months thereafter. | All participants experienced normal height growth. Throughout the follow-up period, no deviations from attained height growth curves were observed. Two female patients experienced weight loss (at ages 10 and 17, respectively) that crossed below 2 major attained-weight percentiles during clinic participation. One child had anorexia nervosa. | Compliance with recommended exercise activities was not evaluated. Estimates of dietary compliance were performed based on diaries collected periodically throughout the study.
| | Cardiovascular health clinic, US | | | | | 47.6% female | Dietary counseling, including review of 3 to 5-day diaries, was performed every 6 weeks up to 1 year after the initial visit, and subsequently every 3 to 6 months. | The other child entered the clinic eating a parent-instituted “vegetarian diet” that was more restrictive than the prescribed AHA-Step-One Diet.
Copperman, 1995 ^270^ | Nutrient quality of fat- and cholesterol-modified diets of children with hyperlipidemia | Cross-sectional case comparison tertiary care ambulatory pediatric atherosclerosis prevention center | To assess the nutritional adequacy of low-fat, low-saturated fat, low-cholesterol-modified diets of children with hyperlipidemia. | At least 1 year | All children in the study were from white middle-class families from suburban New York City area. Hyperlipidemic children were referred to the Schneider Children's Hospital Center for Atherosclerosis Prevention for evaluation and treatment. Controls consisted of 4th and 5th-grade children from a local elementary school recruited from 2 classes. These children were free of chronic illness and were consuming unrestricted diets. | 54 | Mean age 10.8 | Subjects received individual nutrition counseling on a NCEP-Step-1 diet from a registered dietitian. Subjects and controls attended separate training sessions in which a registered dietitian instructed the children and/or families on the accurate completion of the food record and a food frequency questionnaire. | There was no significant difference in consumption of energy, minerals, or vitamins D and E between the groups. The children with hyperlipidemia consumed significantly more vitamin A (p<0.005). | NR
| | | | | | | 54% female
DISC Collaborative Research Group, 1995 ^219^ | Efficacy and safety of lowering dietary intake of fat and cholesterol in children with elevated low-density lipoprotein cholesterol: The dietary intervention study in children (DISC) | RCT | To assess the efficacy and safety of lowering dietary intake of total fat, saturated fat, and cholesterol to decrease LDL-C levels in children | 3 years | 1 Girls aged 7 years, 10 months – 10 years 1 month; boys aged 8 years, 7 months – 10 years, 10 months; 2 Average of 2 screening LDL-C values ≥ 80th and < 90th percentile for age and sex.; 3 No medication or medical condition that could effect growth or blood cholesterol; 4 No behavior problems in child or family likely to reduce adherence; 5 Prepubertal; 6 No plans to move within the 3 study years | 663 (362 boys, 301 girls) | Mean age: boys 9.7 | Randomized to diet (334) or usual care (329). | No differences between groups in adjusted mean height, serum ferritin levels, or other safety measures. | Attendance at intervention sessions averaged 96% during the first 6 months, 91% during the second 6 months, 91% during the second year, and 89% during the third year. | Rated good quality
| | 6 centers | | | | | girls 9.0 | Diet: Behavioral intervention to promote adherence to a diet providing 28% of energy from total fat, less than 8% from saturated fat, up to 9% from polyunsaturated fat, and less than 75/mg (1000 kcal) per day of cholesterol (<150 mg/day). Family oriented, based on social learning and social action theory. 1st visit: eating pattern assessed and personalized program developed. In the 1st 6 months: 6 weekly and then 5 biweekly group sessions augmented by 2 individual visits of children with their family members. In the 2nd 6 months, 4 group and 2 individual sessions. Years 2 and 3: group individual and maintenance sessions held 4–6 × per year with monthly phone contacts between sessions. | Serum ferritin decreased in both groups and the intervention group had slightly lower mean ferritin concentrations than did usual care at year 3 (p=0.08). In both groups, mean ferritin concentrations remained above the 75th percentile for age and sex.
| | Prepubertal boys and girls recruited from public and private elementary schools, by mass mailings to members of an HMO, and from pediatric practices | | | | | | Usual care: Public educational publications on heart-healthy eating provided. Parents informed if child blood cholesterol high - no specific recommendations to see physician given. 3-year lipid results provided, with referral as clinically warranted. | Risk of consuming less than 2/3 of the RDA was significant for vitamin E at all visits (baseline OR: 1.009; year 1 OR: 1.007; year 3 OR: 1.007; p<0.0001 for all visits); for zinc at all visits for boys (baseline OR: 1.004, p<0.05; year 1OR: 1.003, p<0.02, and year 3 OR: 1.004, p<0.003) and girls (baseline OR:1.007, p<0.001: year 1 OR: 1.008, p< 0.0006 and year 3 OR: 1.005, p < 0.003).
Feoli-Fonseca, 1998 ^282^ | Familial lipoprotein lipase deficiency in infancy: clinical, biochemical, and molecular study | Retrospective, descriptive study, Quebec, Canada | To describe the clinical and biochemical features of familial LPL deficiency presenting in infancy, to evaluate the safety and efficacy of severe dietary fat restriction, and to define the LPL gene defects responsible for the disease. | 23 years reviewed; mean duration of follow-up per patient was 6.76 years | Charts were reviewed for all patients with chylomicronemia who attended the lipid clinic of Hospital Sainte-Justine between 1972 and 1995. Inclusion criteria: presentation before 1 year of age, French-Canadian ancestry, and initial plasma TG > 10 mmol/L. 18 were selected; 16 were found to have LPL enzyme deficiency. To assess safety, the authors compiled available weight, height, and sex maturation stage data during the follow-up period, and hemoglobin levels and blood chemistry values of iron, alkaline phosphatase, total calcium, red blood cell folate, and albumin. | 16 | All patients were diagnosed at age <1 year. | Dietary intervention was started in infancy at the hospital. Patients were first given an electrolyte solution intravenously or orally. Fats were progressively reintroduced to reach a level of 5% to 7% of energy as long-chain TG. Solid foods were added after 4 months. At 1 year of age the special formula was replaced by skim milk, and lean protein foods progressively added. Diet provided at most 10% of energy as long-chain TG. | 2 children had abdominal pain requiring hospitalization, and another had a documented episode of acute pancreatitis 2 months after the introduction of an oral contraceptive agent. | NR
| | | | | | | 62.5% female | | No persistent adverse effects on growth were seen. Abnormal values were observed for serum iron, alkaline phosphatase, and total calcium.
| | | | | | | | | All erythrocyte folate (15 measurements, 8 patients) and albumin (41 measurements, 11 patients) levels were within the normal range.
Jacobson, 1998 ^280^ | Normal growth in high-risk hyperlipidemic children and adolescents with dietary intervention | 3-year longitudinal descriptive study | To assess the safety and efficacy of lowering dietary intake of total fat, saturated fat, and cholesterol in growing children and adolescents with severe hyperlipidemia. | 3 years | All children were diagnosed with hyperlipidemia and had been referred by their pediatricians. Patients who were older than age 15 at the first visit were excluded in order to minimize the effects of cessation of growth follow gin puberty. Subjects with secondary hyperlipidemia caused by hepatic, renal, or thyroid disease were also excluded. TC > 95th percentile for age, and had at least 3 visits over 3 years. Follow-up visits were at 3- to 6- month intervals. | 138 | Age range 2–15 | Diet restricting total fat content to 30% of total calories, and saturated fat to 10% of total calories. Anthropometric measures, lipid profiles, and dietary assessment were obtained at each visit. | The participants grew as expected during the follow-up period. There was no significant change in height or weight percentile, expressed as Z score, from baseline to 3-year follow-up. | NR
| | | | | | | 46% female
| | | | | | | 84.1% white, 5.9% African-American, 8.7% Hispanic, 1.5% other race
Kaistha, 2001 ^285^ | Overrestriction of dietary fat intake before formal nutritional counseling in children with hyperlipidemia | Cross-sectional study | To assess the nutritional adequacy of the diets of children with hyperlipidemia following medically unsupervised low-fat diets compared with children receiving unrestricted diets. | N/A: cross-section | Children with hyperlipidemia were selected from patients referred Apr 1, 1996 to Dec. 31, 1997 to the Children's Cardiovascular Health Center (CCHC) at Columbia-Presbyterian Medical Center. 46 were found to be meeting current NCEP Step I diet recommendations for total fat (<=30% of calories). | 46 c/ hyperlipidemia | Mean age 9.7 | At baseline, children and parents were given a 3-day food record with detailed instructions and training by a registered dietitian. | A significantly (p<0.05) greater proportion of children with hyperlipidemia consumed below 75% of the RDA/DRI for Vitamin E and calories, compared with controls. 90% of the decrease in caloric intake could be accounted for by a decrease in total fat intake. | N/A: cross-section | Authors comment that the findings suggest that without formal nutritional counseling, parents of children with hypercholesterolemia may inadvertently overrestrict calories in their children's diet by attempting to eliminate obvious sources of dietary fat.
| | | | | Exclusions: TG ?400 mg/dL or homozygous LDL-C receptor deficiency. | 34 healthy controls | 47% female | Children were asked to complete 3 days of food records, including 2 weekdays and 1 weekend day. No dietary counseling or guidance was given to children or parents at the time of diet-monitoring instruction. Anthropometric data were obtained at baseline, and nutrient intakes were analyzed. | Many children in both groups also did not meet the RDA for folate and calcium, but between-group differences were not significant.
| | | | | Controls were recruited from local pediatric practices in the vicinity of the Medical Center. Controls were invited if their parents stated they were healthy, were free of chronic illness, and were not following a modified or restricted diet. | | 57% Latino
| | | | | | | 43% white
Kuehl, 1993 ^227^ | Effective control of hypercholesterolemia in children with dietary interventions based in pediatric practice. | RCT of parental and family education | To identify and characterize a family-based group intervention to lower plasma cholesterol in children. | 33 weeks | Children referred by physicians who participated in a seminar on the risk factors for atherosclerosis in children, identification and management of high cholesterol in children. 14 pediatric practices referred 295 children. | 295 children randomized to either a single session intervention (SSI) or a multi-session intervention (MSI) | SSI group: | 1 SSI=one 90 minute nutrition education session for patient, siblings and parents (slides presentation, low fat food prep and tasting, distribution of fruit and cereal). “Returned for subsequent food sampling with nutritionist present” but no further formal education.; 2 MSI= four 90 minute sessions with focus on food preparation for breakfast, snack, lunch and dinner. Received notebooks with nutrition information and recipes, incentives for attendance and completion of behavioral contracts (eating low fat meal) | Both groups maintained iron intake at over 87% and calcium intake at over 81% of the RDA throughout the study. % RDA of iron reported baseline to visit 2: MSI 103+/-5 to 98+/-5 (pNS); SSI 87+/-4 to 90+/-4 (p=NS). | “Compliance with providing food records was excellent during the intevervention.” | Poor quality:
| | USA in children with TC ≥185 | | | | | mean age 6.6 | SS outcomes were measured at baseline, 8.5 weeks and 21 weeks | All patients "grew linearly with a mean height increase of 2.0+/-0.3 inches in the MSI group and 2.0+/-0.1 in the SSI group. Both groups had a mean weight increase of 4.1 lbs. Growth parameters not significantly different between the two groups. | | Large and unequal drop out rates (35% for SSI and 16% for MSI) and analyses only use those who completed the second blood draw (215 of original 295); ie not intention to treat.
| | ages 2–15 (mean 7) | | | | | gender: NR | MSI outcomes were measured at baseline, 9 weeks and 33 weeks | | | No assessment of intervention fidelity.
| | | | | | | race: NR | | | | 18% of MSI and 20% of SSI had plasma TC values <170 and were excluded from the analyses because they didn't meet the initial referral criteria of TC ≥185.
| | | | | | | MSI group:
| | | | | | | mean age 7.6
| | | | | | | gender NR
| | | | | | | race NR
Lavigne, 1999 ^281^ | A cholesterol-lowering diet does not produce adverse psychological effects in children: three-year results from the dietary intervention study in children | RCT | To describe the 3-year psychosocial safety results of the DISC study, in which a wide range of possible behavior and cognitive problems were assessed. | Mean length of follow-up 36.2 months | Children were eligible if the average of 2 LDL screening values was between 80–98th percentile, aged 8–10, and prepubescent (Tanner Stage 1). | 663 | Aged 8–10 | A total of 663 8- to 10-year-old children with elevated LDL were randomly assigned to either an intervention or a usual-care group. Intervention included group and individual counseling sessions to assist participants in adopting a dietary pattern containing 28% or less of calories from total fat (<8% saturated fat, up to 9% polyunsaturated fat, and 11% as monounsaturated. fat) and dietary cholesterol intake of less than 75 mg/1000 kcal. | 3-year results showed no adverse effects of treatment in academic function, psychological symptoms, or family function. When statistically significant effects were observed, they generally indicated a beneficial effect from the dietary intervention. | Compliance not reported. A total of 96% of the intervention and 92% of the usual-care participants returned for the 3-year follow-up visit.
| | 6 centers | | | Exclusions were taking medication that affected growth or cholesterol; onset of puberty, non-English speaking; in a remedial special education class; high parental alcohol consumption; or total behavior problem score on CBCL >98th percentile. | | 47% female | Psychological measures included academic achievement (W-J), family cohesion or conflict (FES), total behavior problems (CBCL), diagnosed eating disorders and suicide threats, trait anxiety (STAIC), or depression (CDI). | At 3 years, there were no significant treatment group differences in CBCL total behavior problem, externalizing, or internalizing scores.
| | Prepubertal boys and girls recruited from public and private elementary schools, by mass mailings to members of an HMO, and from pediatric practices | | | | | | | However, the intervention group scored significantly lower on CBCL Thought Problems and Social Competence subscales. Intervention-group girls had lower CBCL Anxious-Depressed subscale scores than usual-care-group girls (-0.029, p<0.05). There were no treatment group differences in CBCL Aggression or Conduct Problem subscale scores. Self-reports of anxiety showed no differences between groups, but self-reports of depression were significantly lower for the intervention group than for the usual-care group (-0.75, p<0.05)
Lifshitz, 1989 ^278^ | Growth failure - a complication of dietary treatment of hypercholesterolemia | Observational study, US | To describe 8 patients with growth failure among a group of 40 children who were advised by their pediatricians to eat a low-fat, low-cholesterol diet for the treatment of hypercholesterolemia. They consumed inappropriate diets with insufficient energy and micronutrients to sustain normal growth and weight gain. | Mean time from dx to nutritional consultation: 20.1 mos. for patients with growth failure; 3.9 mos. for patients without growth failure (p<0.001) | 40 children were referred in 1986-1987 to the Nutrition Center, Division of pediatric endocrinology, North Shore University Hospital in NY because of hypercholesterolemia. The children had no other medical abnormalities. | 40 | 87.5% Tanner Stage I | The referring physician gave general advice to reduce levels of dietary fat and cholesterol at the time of diagnosis. The specific recommendations varied in each case, and implementation by the families was unsupervised. The patients' dietary intake and food patterns were evaluated the Nutrition Center 2 weeks to 4.5 years after diagnosis. Weight and height records throughout life were plotted on standard growth charts. Body composition was assessed by arm measurements as described by Frisancho. | 8 (20%) of 40 patients had growth failure. Three of the 8 had nutritional dwarfing according to the anthropometric indexes of the Welcome Trust Classification, with no progression of puberty. The other 5 had a drop in body weight without linear growth alterations. | NA
| | | | | | | 10% Stage II | | Total dietary energy and zinc content of patients with growth failure were significantly less than those with normal growth. The diets of patients with growth failure provided an average of 66% of energy requirements and 40% of daily zinc requirements for their ideal body weight, age, and sex. Patients with normal growth consumed 84% of the energy requirements, and 58% of daily zinc requirements (p<0.05).
| | | | | | | 2.5% Stage III | | Patients in both groups had similar fat intake: 25.4% with growth failure, 29.6% with normal growth; cholesterol and protein intake were also similar and appropriate (14.6% to 15.9%).
| | | | | | | Mean age at diagnosis 7.7 | | The 3 patients with nutritional dwarfing had inadequate intake of vitamins and minerals: <50% RDA of vitamins B6, D, folacin, zinc, iron, calcium, and magnesium, and <66% of RDA for vitamins A and B12, niacin, and phosphorus. Only vitamins E and C were adequately consumed.
McKenzie, 1996 ^274^ | Change in nutrient intakes, number of servings, and contributions of total fat from food groups in 4- to 10-year-old children enrolled in a nutrition education study | Prospective cohort study, Pennsylvania, US | To determine change in nutrient intakes, number of servings, and contributions of total fat from food groups in children who lowered their dietary fat intake. | 3 months | The CHP was a prospective cohort study (1991-1994) with three groups of children aged 4–10 with hypercholesterolemia (LDL between 80th–98th percentiles) and one age- and gender-matched group of children with normal cholesterol. All children were recruited via their pediatricians' offices in suburbs north of Philadelphia. | 300 children from suburbs north of Philadelphia, PA | aged 4–10 | Participants were assigned randomly to one of four study groups. | Regardless of study group, 74% of all the children failed to consume two thirds of the RDA for vitamin D. Children in this study had on average adequate intakes of all other nutrients, when they reduced their fat consumption. | NR
| | | | | | | | 2 groups of hypercholesterolemic children received different forms of nutrition education: One group of children and their caregivers received face-to-face counseling with a registered dietitian and had free telephone access to the dietitian during the study. The other group was provided with an at-home parenting autotutorial program (PCAT). Both programs promoted NCEP recommendations: total fat ≤30% of energy, ≤10% saturated fat; cholesterol ≤100 mg/1000 kcalories. The third group of hypercholesterolemic children and the control group received no formal nutrition education.
| | | | | | | | Three 24-hour dietary recalls were collected by telephone interview at baseline and 3 months later, and measured for nutrient and food group intakes.
Moreno, 1998 ^275^ | Lymphocyte T Subset Counts in Children with hypercholesterolemia receiving dietary therapy | Descriptive study | To investigate the immunological effects of a step 1 diet from the NCEP in children and adolescents with hypercholesterolemia. | 6 months | Hypercholesterolemic children were recruited from 3 groups: children whose parents presented dyslipoproteinemia; children whose parents suffered from early ischemic heart disease, and children with hypercholesterolemia detected by routine analyses. Excluded immunological diseases, use of corticosteroids or immunosuppressive drugs in previous month, hepatobiliary diseases and/or secondary dyslipoproteinemias. | 42 | Aged 7–15.9 years | Patients and at least one parent met with a pediatric nutritionist who established recommendations based on NCEP Step 1 diet (total fat 30%, saturated fat 10% of total energy). Detailed 24-hr dietary recalls were obtained at baseline, and 6 months after beginning therapy. Physical activity habits were not modified during the study. At baseline and 6 months, fasting blood was analyzed for lipoprotein profile, immunoproteins, and lymphocyte T subsets. | Lymphocyte T subset counts (CD3, CD4, and CD8) showed significant decreases after 6 months of dietary therapy. In all cases, lymphocyte T subset counts remained within normal ranges. Changes in CD3 and CD8 counts were significantly correlated with changes in triglyceride serum levels (p<0.05). The other immune indexes (immunoglobulins G, A, M, and complements C3, C4, and Factor B) did not change significantly. | NR
Obarzanek, 2001 ^218^ | Long-term safety and efficacy of a cholesterol-lowering diet in children with elevated low-density lipoprotein cholesterol: seven-year results of the dietary intervention study in children (DISC) | RCT | To evaluate the long-term safety and efficacy of a cholesterol-lowering diet in children with elevated LDL | 4 years | 1 Average of 2 LDL-C values in 80th – 98th sex-specific percentiles for 8 – 10 year old children in a fasting state; 2 No medical conditions or medications that could effect growth or serum cholesterol, behavioral problems or onset of pubertal maturation. | 663 randomized, | Intervention group | Randomized to dietary intervention or control group. | No differences at any data collection point in height or serum ferritin or any differences in an adverse direction in red blood cell folate, serum retinol and zinc, sexual maturation or body mass index. | Intervention attendance diminished from an average of 96% in the first 6 months to 89% during year 3, and 72% during year 5. After year 5, in the last 3 years of intervention, the percentage of intervention children having 2 or more visits per year decreased from 55% to 42% to 37%, and on average 1.8, 1.4, and 1.3 intervention contacts per participant per year were achieved.
| | Six clinical centers in the USA | | | | 334 to intervention | Mean age: 9.5 (.74) | Intervention: Dietary behavioral intervention that promoted adherence to a diet with 28% of energy from total fat,< 8% from saturated fat, up to 9% from polyunsaturated fat, and <75 mg/1000 kcal cholesterol per day.
| | | | | | 329 to control | Female gender: 46% | Control: Usual care - parents informed child's blood cholesterol high and were given educational materials on heart-healthy eating as available to the public. Annual examinations for study-wide measurements.
| | | | | | | Race: 86.5% of entire study sample white | Intervention: 1st six months: 6 weekly and then 5 biweekly group sessions led by nutritionists and behaviorists, and 2 individual sessions with nutritionist. 2nd six months: 4 group and 2 individual sessions. 2nd and 3rd years: group and individual maintenance sessions held 4 – 6 ×/year, with monthly phone contacts between group sessions. 4th year: individualized approach with motivational interviewing and stage of change. 2 group events and 2 individual visits annually, with individual phone contacts “as appropriate”.
| | | | | | | Control group
| | | | | | | Mean age: 9.5 (.70)
| | | | | | | Female gender: 44%
| | | | | | | Race: 86.5% of entire study sample white
Rose, 1976 ^277^ | Primary hyperlipoproteinemia in childhood and adolescence: identification and treatment of persons at risk for premature atherosclerosis | Descriptive study | To identify primary and familial hypercholesterolemia in children and adolescents; perform dietary treatment and continued assessment of effects and side effects of therapy. | 16 patients followed for 1 year; | The populations screened were 936 patients at pediatricians' offices, 1232 inpatients without conditions likely to cause secondary hyperlipidemia, and 1845 patients with congenital heart disease attending the outpatient clinic or being investigated in the cardiac catherization lab. Betalipoprotein cholesterol was quantified in serum from subjects in whom the initial diagnosis was primary hypercholesterolemia and from children with borderline abnormal cholesterol values on repeat examination. Secondary causes of hypercholesterolemia such as diabetes, renal or liver disease, hypothyroidism and dysglobulinemia were excluded. Parents and siblings of affected individuals were screened to assess whether the primary lipid abnormality was familial. | 4013 were screened; 16 cases of primary hyperbetalipoproteinemia were identified | Age range: 1 month to 20 years | A diet low in cholesterol and high in polyunsaturated fats was instituted. | Growth and development of these patients has progressed according to growth percentiles and no side effects of therapy have been detected. | NR
| | Toronto, Canada | | 9 patients followed > 1 year
Sanchez-Bayle, 1994 ^276^ | Diet therapy for hypercholesterolemia in children and adolescents | Observational | To evaluate the effectiveness and compliance of dietary restriction in a group of children and adolescents with hypercholesterolemia, and monitor growth velocity. | 6–24 months (29 for 2 years; 160 for 1 year; 262 for 6 months). | 507 children referred to Nino Jesus Children Hospital after school-based screening showed a total cholesterol value of 200 mg/dL or higher. More complete lipid study was performed after fasting, and those with cholesterol persisting above 200 mg/dL and LDL above 130 mg/dL were included. Of these 471 meeting criteria, 18 did not show up for 1st visit, 38 were unavailable for f/u. | 451 children and adolescents 2–18 years | 211 males (46.8%), 240 females (53.2%) | Dietary treatment was according to the AHA Step-One Diet proceeding to Step-Two Diet when TC persisted above 240 mg/dL after 5 months. | Growth velocity was found to be normal in all subjects. | Follow-up was 100% at 6 months; 42% at 1 year and 6% at 2 years.
| | Spain | | | | | | Dietary counseling was given by one pediatrician to both parents and the child. Detailed written recommendations were given to each family. | | Authors report 69% compliance with diet at 1 year, but data presented for 189 (42%) participants.
| | | | | | | | All subjects were advised as to the necessity of aerobic exercise and dangers of tobacco
Sanchez-Bayle, 2003 ^283^ | Influence of dietary intervention on growth in children with hypercholesterolemia | Prospective descriptive study, Spain | To determine whether a moderately reduced fat diet affects longitudinal growth in children with hypercholesterolemia | Mean 7.42 years | Children who had a TC > 200 mg/dL and LDL > 135 were included. Children with chronic disease were excluded. | 144 children in Madrid, Spain | Age 2–13 y, mean age 5.53 at beginning of treatment | AHA Step-1 diet was implemented, proceeding to Step 2 if TC > 240 persisted after 5 months, as well as OMS 1985 and 10th RDA recommendations for caloric intake by age. Dietary counseling was given to both parents and children by the pediatrician. Compliance was assessed at 1 month, 6 months, and each year using a questionnaire. Patient weight and height were measured each year and compared with growth standards for Spanish children. | Change in Z-score for height was not affected by moderate dietary fat restriction (0.58 baseline to 0.45 endpoint). Subjects had a significant increase in weight (p<0.001), from Z xcore of 0.33 at the beginning of the study, to 0.58 at endpoint. The authors conclude that growth is not influenced by moderate fat restriction. | Assessed but not reported
| | | | | | | 52% female
Segall, 1970 ^272^ | Effects of short-term high-carbohydrate feeding on serum triglyceride of children with familial hypercholesterolemia | Observational | To described the effects of high carbohydrate diet on triglycerides in children with FH. | 10 days | Unclear | 5 children with HeFH (6 total but results presented here without his data). | age range 6–15, 4 female and 1 male | 10 day high carbohydrate diet: 75% of total calories from carbohydrate (of which 75% sucrose); 10% from fat and 15% from protein. Diet was given as normal foods and was isocaloric with home diet prior to intervention. Only 3 of the 5 children had blood levels measured after 10 days. | 1 child lost 1.4 kg. | NR
| | London
Tershakovec, 1998 ^284^ | Growth of hypercholesterolemic children completing physician-initiated low-fat dietary intervention | RCT of dietary intervention | To evaluate the growth of hypercholesterolemic children completing a physician-initiated home-based nutrition education program or standard nutrition counseling to lower dietary fat intake. | 12 months | 1 Mean fasting plasma LDL-C 107–164 mg/dl for boys and 112–164 mg/dl for girls; 2 Free of secondary causes of dyslipidemia; 3 At least 85% but not greater than 130% of ideal body weight | 261 children with hypercholesterolemia recruited from 9 suburban pediatric practices, randomized to home-based education (PCAT) standard nutrition counseling or at-risk control group. | Children aged 3.9 – 9.9 years recruited from 9 suburban pediatric practices | PCAT and counseling groups complied with recommendations of the National Cholesterol Education Program Expert Panel on Blood Cholesterol Levels in Children and Adolescents. | None noted. Outcomes included | NR | Participants were from predominantly white and relatively affluent families; results may not generalize well.
| (PCAT) | USA | | | | Not-at-risk control group randomly selected from children whose TC was not elevated | PCAT group | PCAT: 10 talking books lessons and follow-up pencil/paper activities for children with manual for parents based on social cognitive theory. A story and activity completed each week for 10 weeks. | 1 Height; 2 Weight; 3 Skinfold measures; 4 Dietary intake | | Diet evaluated by three 24-hour dietary recalls per assessment period
| | | | | | | Mean age: 6.3 + 0.2 | Counseling: Child and at least 1 parent had 45–60 minute session with a pediatric registered dietitian. | Percent calories from fat was associated with weight z-score (p<0.01), weight for height median (p<0.005), and sum of skinfolds (p<0.05).
| | | | | | | Female gender: 51% | Controls: Not provided educational information or materials | Caloric intake was positively associated with weight (p<0.005) and height (p<0.005) z-scores and weight for height median (p<0.01). After controlling for age, no significant time-related among-group differences were observed for the height or weight z-scores, weight-for-height median, caloric intake, or fat intake. Differences among groups in sum of skinfolds approached significance (p=0.06).
| | | | | | | Counseling group | Measures evaluated at baseline, 3, 6 and 12 months | Authors note results analysis shows these children could consume a relatively low-fat diet (down to 24.3% calories as fat in the lowest fat intake quintile group) and still maintain growth over the subsequent year.
| | | | | | | Mean age: 6.2 + 0.2
| | | | | | | Female gender: 50
| | | | | | | At-risk control group
| | | | | | | Mean age: 6.4 + 0.2
| | | | | | | Female gender: 48%
| | | | | | | Not-at-risk group
| | | | | | | Mean age: 6.4 + 0.2
| | | | | | | Female gender: 51%
| | | | | | | Race of all participants stated as 84 – 99% white.
Tonstad, 1996 ^271^ | Psychosocial function during treatment for familial hypercholesterolemia | Cross-sectional study | To determine whether children treated for FH have a greater psychosocial burden than their peers. | N/A (cross-sectional); children treated for 18 mo-=9 yrs prior to this study | FH diagnosis was made if the child had a TC >259 mg/dL, and if one or both parents and other relatives had TC >300 mg/dL or tendon xanthomas or if the LDL receptor mutation was identified (this was the case in 77%). 5 were excluded for familial combined hyperlipidemia, 3 for HoFH, 1 for a disabling chronic disease, and 1 for mental retardation. | 185 children from 156 families | 44.9% female | Mean years of treatment: 4 (range 1.5–9). Recommended diet was ≤30% total dietary energy from fat, <10% of total energy from saturated fat, and <100 mg cholesterol/1000 kcal. About 2/3 of children had been treated with BABRs at some point. | Overall behavioral and emotional scores of children with FH were similar to scores of a population-based sample. | Results of the FFQ indicated good compliance with the diet, except for a slight increase in saturated fat intake among girls with FH. | Assessments were made by parents and teachers.
| | Norway | | | | | Aged 7–16 | Dietary compliance during the past year was assessed by food frequency questionnaire. Psychosocial assessments included the CBCL, the Teacher's Report Form, the Child Assessment Schedule, and the Children's Global Assessment Score. For a reference group, 2600 children aged 4–16 were sampled from the Norway Central Population Register and mailed the CBCL and TRF. | Mean CBCL scores and TRF scores for FH-children were similar to the reference group. YSR total and externalizing scores were lower in girls with FH than in the population. Total and content area CAS scores were similar for children with FH and the epidemiologic cohort, except for the scores for family, mood, and expression of anger, which were lower in the FH group.
| | | | | | | | | According to the CAS item, none of the children with FH had weight loss or gain indicating the presence of an eating disorder.
Witschi, 1978 ^273^ | Family cooperation and effectiveness in a cholesterol-lowering diet | Observational, uncontrolled study | To study the effect of a family dietary program for the purpose of lowering serum cholesterol | 4 week baseline period followed by 3 week diet change period | families recruited by notices in the academic community, telephone prescreening in the community and letters to volunteers for a prior study. | 91 adolescents | 55% female, age NR | A food record was kept by each participants for two weeks during 4-week baseline period. Each family was assigned a nutritionist who maintained contact throughout the study. The diet was based on AHA guidelines for decreasing dietary cholesterol and saturated fat. Weight and blood samples were taken at beginning and end of baseline period, and days 10 and 21 of the 3-week diet-change period. Samples were assayed for cholesterol analysis. | No significant changes in weight. | Compliance was better among females than males. More than 60% of the families attained an adherence rating of “excellent” or “good” during the diet test.
| | Boston, MA | | | Eligible if 1) an adult and at least one adolescent all living and eating most of their meals at home.
Dietary supplements
Amundsen, 2002 ^41^ | Plant sterol ester-enriched spread lowers plasma total and LDL cholesterol in children with familial hypercholesterolemia | Randomized, double-blind crossover | To assess effect of SE-enriched spread on serum lipids, lipoproteins, carotenoids, fat-soluble vitamins, and physiologic variables in children with FH aged 7 – 12 years. | Study period: 25 weeks with run-ins and washouts | Not specifically noted. Implied:; 1 Parent with hypercholesterolemia; 2 Diagnosed with “definite” or “possible” heterozygous FH; 3 Healthy, with no clinical symptoms of hypercholesterolemia | 38 | Mean age: 10.5 + 1.7 | Exposure: | ALT increased in SE diet 16.8% (p = 0.04). No subjects had plasma concentration of ALT outside the reference concentration at any time. | Children consumed 90.9% of the control spread and 91.7% of the SE spread. 32% of subjects felt that the amount of spread was too large, but 68% were satisfied with the amounts. 46% of subjects could recognize a difference between the 2 spreads but could not identify which was SE, of whom 56% indicated that the SE spread tasted better than the control spread. | Small N
| | Subjects recruited from patient register at Lipid Clinic of National Hospital in Oslo, Norway | | 2 – 8 week treatment periods. | | 2 non-study-related drop-outs; 1 drop out because the amount of spread required to be consumed was too large. | 50% female | In a double-blind crossover, with two 8-week interventions, 38 children with FH consumed 18.2 + 1.5 g SE spread/day, corresponding to 1.60 + 0.13 g SE, or a control spread. Blood samples were analyzed at the start and end of each diet period. | Starting concentration of ALT was significantly lower in the SE diet period compared to control. | | Many children used supplements or vitamins during the study.
| | | | | | | Cholesterol (mmol/L) | Subjects consumed a recommended American Heart Association Step I diet during both intervention periods. | Serum levels of lycopene and B-carotene decreased with SE. After adjustment for lipid changes, differences in B-carotene disappeared; lycopene concentration was still 8.1% lower (p=0.015) in SE compared to control. | | These variables were not analyzed separately.
| | | | | | | total: 7.01 + 1.26 | | Serum levels of retinol were higher in SE, and after lipid standardization: 15.6% (p<0.001) higher than control. | | FH was confirmed by mutation analysis in only 25/38 subjects.
| | | | | | | LDL: 5.39 + 1.42 | | After lipid standardization, ) a tocopherol was 7.1% higher in SE than in control (p=0.027). Authors note results may be influenced by different starting concentrations in SE than control. | | Some included children may not have had FH, as baseline total and LDL cholesterol concentrations were significantly higher in the confirmed FH group.
| | | | | | | HDL: 1.37 + 0.32
| | | | | | | Triacyglycerol (mmol/L) 0.56 + 0.22
Amundsen, 2004 ^287^ | Long-term compliance and changes in plasma lipids, plant sterols, and carotenoids in children and parents with FH consuming plant sterol ester-enriched spread | Open-label trial, following | To look at any sustained long-term effect of plasma lipids and level of compliance following an uncontrolled free intake of plant sterol ester-enriched spread; to measure changes in serum concentrations of non-cholesterol sterols, fat-soluble vitamins and carotenoids in children and their parents during the extended open-label period. | 26 weeks | 41 healthy children were recruited from the patient register at The Lipid Clinic at the National Hospital in Oslo. All subjects were diagnosed with ‘definite’ or ‘possible’ heterozygous FH. The diagnosis was documented by the presence of an FH mutation in 25 of the children. In the other 16 subjects, the responsible mutation was still unidentified. All children were healthy and none had clinical symptoms of hypercholesterolemia or used serum cholesterol-lowering drugs. | 37 | mean 9.6 | 37 children were advised to eat plant sterol ester spread (20 g of spread per day, corresponding to 1.76 g/day of plant sterol). | lipid-adjusted lathosterol levels were stable; sitosterol levels were 77% higher compared to control period of RCT. | Children consumed slightly less spread (14 g/day vs 18 g/day during trial).
| | RCT above | | | | | | Blood samples were taken at weeks 1 and 26. A total of 13 children took fish oil supplements (5 ml/day) and eight children took multivitamin supplements during the study. | Lipid-adjusted retinol levels were 11% higher at the end of the open label period as compared to control. No changes in lycopene or lutein.
| | | | | | | | | lipid-adjusted serum a-carotene increased in the open label period following a decrease in the trial period.
Becker, 1993 ^288^ | Treatment of severe familial hypercholesterolemia in childhood with sitosterol and sitostanol | Open-label clinical study | To compare the ability of two plant sterols to reduce serum lipid levels and to compare their mechanism of action in children with severe HeFH. | 10 months: | 1) family history of hypercholesterolemia and premature coronary artery disease in at least one first-degree family member,; 2) serum cholesterol concentration (TC and LDL) that was on two occasions 1.5 times >95th percentile for age and gender after at least 3 months of strict diet,; 3) exclusion of phytosterolemia, a rare inborn error of hyperabsorption of plant sterols. | 9 children with HeFH | Mean age 11.96 | After a 3-month diet, subjects were given sitosterol pastils (3×2 g/d) for 3 months, followed by a 7-month course of sitostanol (3 × 0.5 g/d). | After dietary intervention, alanine aminotransferase was decreased | All 9 subjects completed the study. Children and parents reported a high degree of acceptance and compliance during all treatments.
| | Germany | | 3 on sitosterol | | | 33.3% female | Safety was assessed by routine lab tests, and abdominal sonography of the liver and gallbladder were performed every 3 months to check for possible gallstone formation. | Decreases in alkaline phosphatase and carotene concentration were noted with sitosterol, but with sitostanol these returned to initial values.
| | | | 7 on sitostanol | | | | | After 7 months of sitostanol, there was a slight but significant increase in transferrin concentration, and the total bile acid concentration in serum was significantly reduced. These changes did not reach abnormal levels.
| | | | | | | | | All other lab values (hemoglobin, leukocyte count, platelet count, calcium, phosphate, lipase, iron, creatinine, and creatine kinase) showed no change.
| | | | | | | | | Weight and height percentiles of all children remained normal throughout the study. No changes in stool pattern were reported. No abnormalities in liver and gallbladder were found.
Clarke, 1990 ^289^ | Increased incidence of epistaxis in adolescents with familial hypercholesterolemia treated with fish oil | Descriptive study | To evaluate the potentially beneficial effect of dietary fish oil supplementation on plasma lipid levels in a small group of adolescent patients with familial hyperlipoproteinemia type II, and to note possible undesirable side effects. | 6 months | Diagnosis of FHL type II was based on a positive family history, typical abnormalities of plasma lipid levels, and absence of evidence of any other condition to account for the lipid abnormalities. All subjects were maintained on their usual modified low cholesterol/low sat. fat diet throughout the study; two also received colestipol, 10 g/day. | 11 | Age 11–21, 63.6% female | After 3 months of pretreatment observation, each subject was given a commercial fish oil supplement (containing 18% eicosapentaenoic acid, 12% other omega-3 fatty acids, and vitamin E) in a dosage started at 1 g/day, and increased by 1 g/day at monthly intervals to a total of 5 g/day for the 5th and 6th months of therapy. | 3 of 11 subjects had prolongation of bleeding time during fish oil supplementation. 8 of the 11 subjects had a total of 9 episodes of epistaxis during 62 subject-months of fish oil treatment; no subject reported any nosebleeds during 43 subject-months of pretreatment and posttreatment observation (p<0.02). One subject experienced prolonged bleeding time ( 9 minutes; control, 3 to 5 minutes). The subject had been receiving 5 g/day of fish oil at the time of withdrawal. | In two subjects, therapy was stopped as a result of epistaxis.
| | Ontario, Canada | | | | | | | Two other subjects experienced epistaxis associated with modest prolongation of the bleeding time (7 minutes); one of these had a history of acetylsalicylic acid ingestion at the time. One subject had asymptomatic occult blood in the stool on one occasion; the bleeding time was normal. None of the subjects had any evidence of liver dysfunction; all prothrombin and partial thromboplastin times and platelet counts were normal.
Dennison, 1993 ^223^ | Randomized, double-blind placebo-controlled, two-period crossover clinical trial of psyllium fiber in children with hypercholesterolemia | randomized cross-over trial of psyllium in children ages 5–17 with LDL>110 mg/dL already being treated with diet, recruited from Pediatric Lipid Control Center and from private pediatricians in the vicinity. | To assess whether psyllium was effect at lowering TC and LDL values in children beyond the reduction achieved by diet alone | 4–5 weeks each period with a 2 week wash-out period between | Children with LDL>110 mg/dL after treatment with diet. | 25 children began the study; 4 did not return for the final blood drawing (3 because of parental difficulties - timing, logistics; 1 boy because he refused to eat the cereal and have his blood redrawn); 1 second blood sample was lost. | 11 males; 9 females | Diet consisted of <30% calories as total fat, <10% as saturated fat and <200 mg dietary cholesterol/day. Total calories enough to ensure adequate growth. | One child (a 17 year old girl reported a transient increase in loose stools (3 /day) with the control cereal with resolved with discontinuation and reappeared with a second challenge of the control cereal and resolved post discontinuation. | Compliance was 82% for both cereals. | baseline lipid levels not different significantly for those (n=5) who did not complete the study.
| | | | | | | age 11.1+3.8 years | Subjects instructed to eat two 28gm servings (1 0z or 2/3 c each) of the control cereal (5 mg water-insoluble wheat fiber per serving) or the psyllium cereal (3 gm of water-insoluble fiber and 3 game water-soluble fiber per serving). Cereals were similar in appearance and provided by same manufacturer. | No changes in subscapular or triceps skin-fold thicknesses. | | Most families were unaware of which cereal was in use (2/3 of children or parents incorrectly identified the psyllium containing cereal).
| | | | | | | | | Height and weight increased equally during consumption of control and psyllium cereals.
| | | | | | | | | None of vitamin or mineral levels tested were lower after the psyllium cereal.
Glassman, 1990 ^290^ | Treatment of Type Iia hyperlipidemia in childhood by a simplified American Heart Association (AHA) diet and fiber supplementation | Descriptive study | To determine whether the AHA Step-One diet would effectively lower serum total and LDL cholesterol levels in children for prolonged periods. | 8.1 (+- 2.4) months | Children with primary type Iia cholesterolemia (evaluated TC with normal or elevated TG concentrations) who were treated at the Children's Nutrition Center of the New York Medical College, Valhalla, between January 1 1988 and December31 1988. These patients were identified during routine screening by their pediatricians and had the diagnosis confirmed by lipoprotein electrophoresis after a 14-hour fast. The children were otherwise in excellent health and were receiving no medications. | 36 | Age range 9–17, mean 9.74 | Patients were treated with a modified version of the AHA Step-One diet at the Children's Nutrition Center of the New York Medical College. The diet, in which a maximum of 10% of the energy intake was derived from saturated fat, did not specifically restrict cholesterol intake or the percentage of total energy ingested as fat. In addition, children under age 7 were required to consume 2.5 g of soluble fiber as psyllium mixed in water twice daily. Children older than 7 received 10 g of psyllium. | All patients tolerated both regimens well without developing abdominal distention or cramping, constipation, diarrhea, or excessive flatus production. There were no changes in serum zinc, copper, or hemoglobin concentrations; hematocrit; mean corpuscular volume; or prothrombin and partial thromboplastin times during the period of study. | All patients tolerated both regimens well.
| | Lipid clinic, New York | | | | | 38.9% female | Each patient was reassessed at 6-week intervals using a 24-hour dietary diary, a food-selection checklist, and a serum lipoprotein electrophoresis. Serum zinc and copper levels, as well as prothrombin and partial thromboplastin times, were measured in 10 patients over the course of therapy.
Gulesserian, 2002 ^291^ | Effect of a rapeseed oil substituting diet on serum lipids and lipoproteins in children and adolescents with familial hypercholesterolemia | Descriptive study | To investigate how adolescents and families with FH would respond to a lipid lowering diet enriched with rapeseed oil and what effects on serum lipids can be observed. | 5 months | HeFH patients were selected from a pediatric outpatient clinic with the following characteristics: plasma TC levels >200 mg/dL), LDL > 130 mg/dL, TG <250 mg/dL, BMI range 10% to 90% percentiles. Of 43 potential subjects, 26 were excluded because they were not able to adhere to the study protocol or did not provide an appropriate dietary protocol. | 43 were enrolled, but analysis includes only 17 | Age range 4–19, median 12.7 | Diet therapy had 2 approaches: 1) replacement of as many visible fats as possible by rapeseed oil (including use preparation of meals, as in frying, baking, and salad dressing) and 2) reduction of dietary cholesterol. High dietary fiber was achieved by prescribing a high quantity of fruits and vegetables. During the study patients met the dietician 7 times, and the pediatrician 6 times. Compliance to the diet was checked by routine 3-day protocols with children and parents. | NR | The diet was well accepted; no patient canceled the study due to dislike of the oil. | 26 enrolled patients were not able to adhere to the study protocol or did not provide an appropriate dietary protocol.
| | Vienna, Austria | | | | | 64.7% female | | | | The report of compliance only includes the patients who adhered to the protocol.
Gylling, 1995 ^39^ | Sitostanol ester margarine in dietary treatment of children with familial hypercholesterolemia | Randomized cross-over trial of diet | To assess the effect of sitosterol rape-seed margarine vs. rape-seed margarine without sitosterol | 6 weeks each arm | Diagnosis of FH established in children and in one parent mostly by DNA technique | 14 children with HeFH and 1 child with HoFH (2 years old) | 7 boys, 7 girls | Children were randomized to replace 24 g of their normal daily fat intake by the same amount of a rapeseed oil-rich margarine with or without sitostanol ester (M vs MS). All children had previously been advised to use a low animal fat-low cholesterol diet rich in monogenic fatty acids for years. Protocol results in daily consumption of 3 gm of free sitostanol in MS group. | Children noted no difference in taste between the two margarines. | Report “good compliance,” and “well tolerated.”
| | 14 children with HeFH | | | | | Mean age 9.1+1.1 (2–15) | | Report “good compliance,” and “well tolerated.”
| | Helsinki, Finland
Laurin, 1991 ^294^ | Effects of a soy-protein beverage on plasma lipoproteins in children with familial hypercholesterolemia | RCT, crossover study | To examine the effects of a beverage based on isolated soy protein in the diet on plasma lipid, lipoprotein-fraction cholesterol, and apolipoprotein concentrations in HeFH children. | 4 weektreatment/4 week washout/4 week crossover treatment | Hypercholesterolemic children from the Quebec City area where the heterozygote frequency of FH is ~2.5-fold higher than in most populations elsewhere. Baseline fasting concentrations of TC and LDL > 95th percentile adjusted for age and sex. Other criteria: detection of hypercholesterolemia in at least 2 first-degree relatives; the presence of tendinous xanthomas or type II-A lipoprotein pattern in 3 generations of relatives, or with compatible autosomal dominant transmission; exclusion of secondary forms of hypercholesterolemia. No subjects had fasting hyperchylomicronemia or type III hyperlipoproteinemia, recent weight loss (within 6 months), acute disease or major surgery in the past 3 months, and allergy to or dislike for milk. | 10 | Mean age 7.9 | 5 subjects per group were randomly assigned to receive either the cow-milk or the soy-beverage diet, with subsequent switch to the other diet in a crossover design, each diet and washout lasting 4 week. During the washout, subjects consumed their regular diet. The soy beverage was formulated to provide similar amounts of protein, carbohydrate, fat, calcium, and phosphorus as 2%-fat cow milk as well as a minimum of 20% of the US RDA of 16 other vitamins and minerals. The nutrient composition of the two experimental diets was comparable with their regular regimen, and the same menus were used for the two experimental periods. | All participants had adequate growth and development as verified by the tracking of each subject against physical-growth charts. | Authors report that good control over mean dietary intake was achieved, as indicated by similar percentages of protein energy consumed as a dairy source in the two experimental diets.
| | Quebec City | | | | | 40% female
McCrindle, 1998 ^235^ | Garlic Extract Therapy in Children with Hypercholesterolemia | DB RCT: | To determine tolerance, compliance, safety, and efficacy of therapy with a commercially available garlic extract in lowering cholesterol in pediatric patients with hypercholesterolemia | 8 weeks | Included patients age 8–18, a positive family history of hypercholesterolemia or premature atherosclerotic cardiovascular disease in first-degree relatives, a minimum fasting TC > 4.8 mmol/L (>185 mg/dL), participation in a dietary counseling program, and compliance with a NCEP Step II diet for at least 6 months. Excluded secondary causes of hyperlipidemia or a history of major surgery or serious illness within 3 months prior to enrollment. | 30 patients age 8–18 | Mean age 14 | Patients were instructed to stop taking lipid-lowering medications for ≥8 weeks prior to the study. Participants were instructed to take 1 capsule (containing 300 mg garlic extract or identical placebo) t.i.d. for 8 weeks. A random number generated list was supplied to an independent pharmacist who assigned patients consecutively when they were enrolled. Logbooks and questionnaires were used. | 1 patient on garlic experienced unpleasant body odor, but had been working concomitantly on a garlic farm during the study period. | 1 patient was unable to swallow the capsules and withdrew.
| | placebo-controlled trial of garlic extract | | | | | 53% male | | The most commonly reported AEs were headache and upset stomach, but reporting of AEs was similar between garlic and placebo groups. | Compliance was similar between garlic and placebo groups. 86% vs 93%, (p=0.34).
| | 30 patients | | | | | | | There were no significant differences between groups in height, weight, blood pressure. The only significant differences in laboratory parameters were in serum albumin level (+2.0 g/L, p=0.002) and hemoglobin (+5.2 g/L, p=0.02) with garlic.
| | | | | | | | | 1 patient was unable to swallow the capsules and withdrew.
| | | | | | | | | Compliance was similar between garlic and placebo groups.
Mietus-Snyder, 1998 ^292^ | Endothelial dysfunction occurs in children with two genetic hyperlipidemias: Improvement with antioxidant vitamin therapy | Non-randomized controlled trial | To confirm the previously-reported finding of impaired endothelium-dependent vascular relaxation in children with FH, to extend these observations to other hyperlipidemic phenotypes and to assess the efficacy of antioxidant vitamin therapy in reducing endothelial dysfunction. | 6 weeks | 1 Good health and diagnosed with heterozygous FH (LDL > 95th percentile, normal triglycerides, affected parent) or familial combined hyperlipoproteinemia (LDL or fasting triglycerides > 95th percentile, parent with 1 of 3 phenotypic presentations of FCH) | 45 | Mean age: 12.5 | Exposures: Combined regimen of partial difference-alpha tocopherol (400 IU twice a day) and vitamin C (500 mg twice a day) for 6 weeks. At follow-up the protocol was repeated except for nitroglycerin administration. | No adverse effects of antioxidant vitamin therapy reported. | “All subjects tolerated the study well, although approximately 1/3 complained of a transient, mild headache after nitroglycerin administration, coincident with a 10 to 20 mm Hg decrease in systolic pressure.” | Small sample size
| | 33 of 45 subjects were members of families followed in a lipid clinic. | | | | 11 received treatment | 56% female | Brief medical history, physical exam, and nutritional counseling including American Heart Association diet guidelines. | | | Short follow-up
| | Control Group: | | | | No withdrawals reported | | Vascular reactivity in brachial artery measured with high-resolution two-dimensional ultrasonography. Primary outcome was change in brachial artery diameter in response to either hyperemia or sublingual administration of nitroglycerin
| | Unaffected siblings or children with normal lipid profiles | | | | 18 subjects with FH
| | | | | | 15 subjects with FCH
| | | | | | 12 controls
Sanchez-Bayle, 2001 ^293^ | The effect of fiber supplementation on lipid profile in children with hypercholesterolemia | Observational study, Spain | To assess the effects of fiber supplements on lipid levels in children with dyslipidemia who were following a dietary treatment. | 3 months | Children with persistently elevated LDL (>135 mg/dL) after a minimum of 6 months dietary treatment (<30% calories as total fat, <10% as sat. fat, and <300 mg dietary cholesterol per day) were recruited from Hospital Nino Jesus in Madrid from 1989 to 1990. As a control group, 33 children with persistently elevated LDL were recruited from 1992 to 1993. | 53 children in Madrid, Spain | Mean age 7.3 (range 4–18) | In addition to dietary restriction, children were given fiber supplements for 3 months in tablets that contained 50% wheat bran and 50% pectin and were given 2 to 3 times per day at doses of 50 mg/kg/day. Compliance with diet and fiber supplementation was confirmed by interview. Diet was assessed by a food frequency questionnaire and a 24-hour recall. Control families were instructed to maintain their current dietary restriction and subjects were re-evaluated 3 months later. | Two children reported abdominal discomfort and soft stools and refused to continue the study. | Fiber supplements were generally well tolerated except for two children who withdrew due to abdominal discomfort.
Schlierf, 1978 ^295^ | Sitosterol in juvenile type II hyperlipoproteinemia | Randomized cross-over trial comparing verum (sitosterol) to placebo; 3 months each treatment. | To determine the effect of verum to placebo | 6 months, 3 on sitosterol | NR | 15 children and adolescents, randomized to receive either sitosterol | Age 8–20 | Treatment: 12g of B-sitosterol granulate with 20g NaBr | 3 patients terminated the study before completion, unclear reasons; in the other 12 plasma bromide levels, drug intake sheets and used med packs indicated good compliance. | 3 of the 15 patients withdrew before completion. In the remaining 12 patients, plasma bromide levels, drug intake control sheets, and the returned packs of unused medication indicated good adherence to the study protocol. | Poor quality
| | West Germany | | | | (n=7)or placebo first | | Placebo: 20g of NaBr with 12 g cellulose. Each taken in 3 portions of 4g, 30 minutes before meals. | Sitosterol levels 0.88±0.24 in placebo group vs 1.48±0.62 in sitosterol group. | | results lumped after 6 months (no pre-cross over data).
| | | | | | (n=8) | | | | | No wash-out period.
| | | | | | | | | | | Authors comment that this not probably recommended for use in children because of increases in HDL and sitosterol levels.
Zavoral, 1983 ^296^ | The hypolipidemic effect of locust bean gum food products in familial hypercholesterolemic adults and children | Non-randomized, crossover study | To assess the hypolipidemic effect of locust bean gum food products. | 8 weeks | Normal and familial hypercholesterolemia patients were selected from the Hennepin County Medical Center's Hyperlipidemia Clinic. All of the families had one parent and child and at least one additional first degree relative with FHC. | 11 children | Aged 10–18 | Identical food products with and without locust bean gum (LBG) were consumed by two groups of arbitrarily assigned patients using a cross-over design. The food products contained 8 to 10% LBG by dry weight. Each portion contained between 1.7 and 2.0 g of LBG. LBG in the food products was prescribe to the subjects on the basis of body size. Families were seen at 2-week intervals, and dieticians collected 3-day diet histories and 2week dietary records for the food products. Safety assessments included WBC counts, calcium, and SGOT before and after feedbing LBG food products. | There was no change observed in the white blood cell counts, serum calcium, or SGOT determinations. | Children ate the prescribed amount of LBG food products.
| | | | | | | | | Subjects reported increased rectal gas while on the LBG-containing products, but decreased and at 1–2 weeks the amount of gas reported was usually not a problem. No one had diarrhea, and stool size increased slightly. One patient had significant constipation that remitted after discontiuing the diet for 3 days. This subject was able to resume the diet without further problems. | Author states “LBG food acceptance was good, and there were no significant side effects.”
Exercise
Kavey, 1997 ^298^ | Valvular and pediatric congenital heart disease - exaggerated blood pressure response to exercise in children with increased low-density lipoprotein cholesterol | Cross-sectional study, US | To compare the blood pressure response to exercise in a group of children with increased LDL with the response in a group of normal control subjects. | 0 (cross-sectional study) | The study group consisted of boys aged >10 with LDL ≥160 mg/dL who had been referred to the Pediatric Preventive Cardiology clinic over a 2-year period. Higher SBP on termination of exercise in these children was evaluated by using a retrospective control group consisting of boys 10–18 with normal results on cardiac examination who had undergone elective treadmill exercise testing during the same period. Children with relative weight >120% were excluded from both groups. | 15 hypercholesterolemic children; 32 control children | Age 10–17, mean 12.7 | Treadmill exercise tests were performed on a cardioexercise treadmill, using published protocol and pediatric normal data for maximum predicted heart rate and endurance time. Blood pressures were measured in the right arm at rest before beginning exercise, immediately after termination of exercise, and then every 2 minutes during recovery. | Combined results for retrospective and prospective comparisons: Children with severely increased LDL cholesterol had an exaggerated blood pressure response to exercise when compared with normolipidemic control subjects. Children with increased LDL had significantly higher systolic and diastolic blood pressures before treadmill exercise (S 120 vs 113 mmHG, p<0.03; D 68 vs 63 mmHg, p<0.01). Among children with high LDL, blood pressures were significantly higher after exercise (S 182 vs 160 mmHg, p<0.0003; D 77 vs 72 mmHg, p<0.03), and systolic blood pressures remained significantly higher at the end of recovery (120 vs 112 mmHg, p<0.005. | NR
| | | | | A prospective evaluation was also undertaken: 10 hypercholesterolemic boys with LDL >160 mg/dL and 10 age-matched control subjects age 10–17 were examined by the same protocol. | | 0% female
Tolfrey, 1998 ^297^ | Exercise training induced alterations in prepubertal children's lipid-lipoprotein profile | Observational pre-test/post-test | Examine effect of exercise training on prepubertal children's lipid-lipoprotein profile | 12 weeks | 1 Volunteered for study after attending school-based presentation and visiting university exercise physiology lab.; 2 Determined by medical screening to be healthy and asymptomatic.; 3 No medication known to effect lipid profile. | 48 enrolled | Mean age: 10.6 (0.7) | Exercise Training Group (ET): | NR | 100% adherence to training program reported
| | Recruitment from primary schools | | | | ET group: 28 | 50% female | Supervised stationary cycling for 30 minutes, 3×/week for 12 weeks at 79.3% (+ 1.2) peak heart rate
| | England | | | | Control group: 20 | | Control group: Maintained their usual lifestyle pattern
| | February – July 1995 (ET)
| | February – July 1996 (Control)