# References

1 Ahmed SM, Clasen ME, Donnelly JE. Management of dyslipidemia in adults. Am Fam Physician. 1998;57(9):2192-2204. [pmid: 9606309].
2 Dorlands Illustrated Medical Dictionary. 29th ed. Philadelphia, PA: W.B. Saunders Company; 2000.
3 Kelder SH, Osganian SK, Feldman HA, et al. Tracking of physical and physiological risk variables among ethnic subgroups from third to eighth grade: the Child and Adolescent Trial for Cardiovascular Health cohort study. Prev Med. 2002;34(3):324-333. [pmid: 11902849].
4 Klag MJ, Ford DE, Mead LA, et al. Serum cholesterol in young men and subsequent cardiovascular disease. N Engl J Med. 1993;328(5):313-318. [pmid: 8419817].
5 Eyre H, Kahn R, Robertson RM, et al. Preventing cancer, cardiovascular disease, and diabetes: a common agenda for the American Cancer Society, the American Diabetes Association, and the American Heart Association. Circulation. 2004;109(25):3244-3255. [pmid: 15198946].
6 Morrison JA. A longitudinal evaluation of the NCEP-Peds guidelines for elevated total and LDL cholesterol in adolescent girls and boys. Prog Pediatr Cardiol. 2003;17:159-168.
7 Whitlock EP, Williams SB, Gold R, Smith P, Shipman S. Screening and interventions for childhood overweight: systematic evidence synthesis. Evidence Synthesis #36. Rockville, MD: Agency for Healthcare, Research, and Quality; 2005.
8 Srinivasan SR, Myers L, Berenson GS. Predictability of childhood adiposity and insulin for developing insulin resistance syndrome (syndrome X) in young adulthood. Diabetes. 2002;51:204-209. [pmid: 11756342].
9 Ford ES, Ajani UA, Mokdad AH. The metabolic syndrome and concentrations of c-reactive protein among U. S. youth. Diabetes Care. 2005;28(4):878-881. [pmid: 15793189].
10 Goodman E, Dolan LM, Morrison JA, Daniels SR. Factor analysis of clustered cardiovascular risks in adolescence: obesity is the predominant correlate of risk among youth. Circulation. 2005;111:1970-1977. [pmid: 15837951].
11 Kavey R-EW, Daniels SR, Lauer RM, Atkins DL, Hayman LL, Taubert K. American heart association guidelines for primary prevention of atherosclerotic cardiovascular disease beginning in childhood. J Pediatr. 2003;142(4):368-372. [pmid: 12712052].
12 Williams CL, Hayman LL, Daniels SR, et al. Cardiovascular health in childhood: A statement for health professionals from the Committee on Atherosclerosis, Hypertension, and Obesity in the Young (AHOY) of the Council on Cardiovascular Disease in the Young, American Heart Association. Circulation. 2002;106(1):143-160. [pmid: 12093785].
13 Oregon Evidence-based Practice Center (EPC). Screening for Dyslipidemia in Adults: Brief Update of 2001 USPSTF Review. Rockville, MD: Agency for Healthcare, Research, and Quality; 2006 (in press).
14 The Lipid Research Clinics Population Studies Data Book. Vol 1. Bethesda, MD: National Institutes of Health; Lipid Metabolism Branch; Division of Heart and Vascular Diseases; National Heart, Lung, and Blood Institute.; 1980.
15 Srinivasan SR, Sharma C, Foster TA, Berenson GS. Longitudinal changes of serum lipid and apoB levels in a newborn-infant cohort. Metab: Clin & Exp Feb. 1982;31(2):167-171.
16 Schrott HG, Bucher KA, Clarke WR, Lauer RM. The Muscatine hyperlipidemia family study program. Prog Clin Biol Res. 1979;32:619-646. [pmid: 523488].
17 Freedman DS, Shear CL, Srinivasan SR, Webber LS, Berenson GS. Tracking of serum lipids and lipoproteins in children over an 8-year period: the Bogalusa Heart Study. Prev Med. 1985;14(2):203-216. [pmid: 4048083].
18 Freedman DS, Dietz WH, Srinivasan SR, Berenson GS. The relation of overweight to cardiovascular risk factors among children and adolescents: the Bogalusa Heart Study. Pediatrics. 1999;103(6 Pt 1):1175-1182. [pmid: 10353925].
19 Bao W, Srinivasan SR, Valdez R, Greenlund KJ, Wattigney WA, Berenson GS. Longitudinal changes in cardiovascular risk from childhood to young adulthood in offspring of parents with coronary artery disease: the Bogalusa Heart Study. JAMA. 1997;278(21):1749-1754. [pmid: 9388151].
20 Newman WPI, Freedman DS, Voors AW, Gard PD, et al. Relation of serum lipoprotein levels and systolic bolld pressure to early atherosclerosis. N Engl J Med. 1986;315:138-144. [pmid: 3455748].
21 Freedman DS, Newman WP 3rd, Tracy RE, et al. Black-white differences in aortic fatty streaks in adolescence and early adulthood: the Bogalusa Heart Study. Circulation. 1988;77(4):856-864. [pmid: 3258194].
22 Berenson GS, Wattigney WA, Tracy RE, et al. Atherosclerosis of the aorta and coronary arteries and cardiovascular risk factors in persons aged 6 to 30 years and studied at necropsy (The Bogalusa Heart Study). Am J Cardiol. 1992;70(9):851-858. [pmid: 1529936].
23 Berenson GS, Srinivasan SR, Bao W, Newman WP 3rd, Tracy RE, Wattigney WA. Association between multiple cardiovascular risk factors and atherosclerosis in children and young adults. The Bogalusa Heart Study. N Engl J Med. 1998;338(23):1650-1656. [pmid: 9614255].
24 Strong JP, Zieske AW, Malcom GT. Lipoproteins and atherosclerosis in children: an early marriage?. Nutr Metab Cardiovasc Dis. 2001;11(Suppl 5):16-22. [pmid: 12063771].
25 Kwiterovich PO Jr. Prevention of coronary disease starting in childhood: what risk factors should be identified and treated?. Coron Artery Dis. 1993;4(7):611-630. [pmid: 8281366].
26 Pathological Determinants of Atherosclerosis in Youth (PDAY) Research Group. Relationship of atherosclerosis [in young men] to serum lipoprotein cholesterol concentrations and smoking. JAMA. 1990;264:3018-3024. [pmid: 2243430].
27 Goldstein JL, Hobbs HH, Brown MS. Familial hypercholesterolemia. In: Seriver CR, Beaudet AL, Sly WS, Valle D, eds. The metabolic basis of inherited disease. Vol 120. New York: McGraw-Hill; 2001.
28 Clauss SB, Kwiterovich P. Genetic disorders of lipoprotein transport in children. Prog Pediatr Cardiol. 2003;17:123-133.
29 Laskarzewski PM, Khoury P, Kelly K, Mellies MJ, Morrison JA, Glueck CJ. Prevalence of familial hyper- and hypolipoproteinemias in Blacks: the Princeton School District Family Study. Prev Med. 1982;11(2):142-161. [pmid: 7088903].
30 Austin MA, Hutter CM, Zimmern RL, Humphries SE. Genetic causes of monogenic heterozygous familial hypercholesterolemia: a HuGE prevalence review. Am J Epidemiol. 2004;160(5):407-420. [pmid: 15321837].
31 Kwiterovich PO Jr. Diagnosis and management of familial dyslipoproteinemia in children and adolescents. Pediatr Clin North Am. 1990;37(6):1489-1523. [pmid: 2259550].
32 Cortner JA, Coates PM, Gallagher PR. Prevalence and expression of familial combined hyperlipidemia in childhood. J Pediatr. 1990;116(4):514-519. [pmid: 2319396].
33 Cortner JA, Coates PM, Gallagher PR. Prevalence and expression of familial combined hyperlipidemia in childhood. J Pediatr. 1990;116(4):514-519. [pmid: 2319396].
34 National Cholesterol Education Program (NCEP). Report of the expert panel on blood cholesterol levels in children and adolescents. Pediatrics. 1992;89(3 Pt 2):525-584. [pmid: 1538956].
35 American Academy of Pediatrics. Committee on Nutrition. Cholesterol in childhood. Pediatrics. 1998;101(1 Pt 1):141-147. [pmid: 11345978].
36 American Heart Association. Step I, Step II, and TLC Diets. http://www.americanheart.org/presenter.jhtml?identifier=4764. Accessed April 29, 2005.
37 Wiegman A, Hutten BA, de Groot E, et al. Efficacy and safety of statin therapy in children with familial hypercholesterolemia: a randomized controlled trial. JAMA. 2004;292(3):331-337. [pmid: 15265847].
38 Clauss SB, Holmes KW, Hopkins P, et al. Efficacy and safety of lovastatin therapy in adolescent girls with heterozygous familial hypercholesterolemia. Pediatrics. 2005;116(3):682-688. [pmid: 16140708].
39 Gylling H, Siimes MA, Miettinen TA. Sitostanol ester margarine in dietary treatment of children with familial hypercholesterolemia. J Lipid Res. 1995;36(8):1807-1812. [pmid: 7595101].
40 de Jongh S, Vissers MN, Rol P, Bakker HD, Kastelein JJ, Stroes ES. Plant sterols lower LDL cholesterol without improving endothelial function in prepubertal children with familial hypercholesterolaemia. J Inherit Metab Dis. 2003;26(4):343-351. [pmid: 12971422].
41 Amundsen AL, Ose L, Nenseter MS, Ntanios FY. Plant sterol ester-enriched spread lowers plasma total and LDL cholesterol in children with familial hypercholesterolemia. Am J Clin Nutr. 2002;76(2):338-344. [pmid: 12145004].
42 Tammi A, Ronnemaa T, Miettinen TA, et al. Effects of gender, apolipoprotein E phenotype and cholesterol-lowering by plant stanol esters in children: the STRIP study. Special Turku Coronary Risk Factor Intervention Project. Acta Paediatr. 2002;91(11):1155-1162. [pmid: 12463311].
43 U.S. Preventive Services Task Force. Screening for lipid disorders: recommendations and rationale. http://www.ahrq.gov/clinic/ajpmsuppl/lipidrr.pdf. Accessed April 29, 2005.
44 Pignone MP, Phillips CJ, Lannon CM, et al. Screening for lipid disorders. Rockville, MD: Agency for Healthcare, Research, and Quality; 2001. Systematic Evidence Review Number 4.
45 National Cholesterol Education Program Expert Panel on Detection E, Treatment of High Blood Cholesterol in A. Third Report of the National Cholesterol Education Program (NCEP) Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel III) final report. Circulation. 2002;106(25):3143–3421.
46 National Cholesterol Education Project. Highlights of the report of the Expert Panel on Blood Cholesterol Levels in Children and Adolescents. Pediatrics. 1992;89(3):495-501. [pmid: 1741227].
47 Slavin RE. Best practice synthesis: An alternative to meta-analytic and traditional reviews. Education Res. 1986;15:5-11.
48 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force. A review of the process. Am J Prev Med. 2001;30(3S):21-35. [pmid: 11306229].
49 Thompson D, Edelsberg J, Colditz GA, Bird AP, Oster G. Lifetime health and economic consequences of obesity. Arch Intern Med. 1999;159(18):2177-2183. [pmid: 10527295].
50 Helfand M, Carson S, Kelley C. Drug Class Review on Statins. Final Report. http://www.ohsu.edu/drugeffectiveness/reports/documents/Statins. Accessed June 15, 2005.
51 National Heart Lung and Blood Institute. Cardiovascular profile of 15,000 children of school age in three communities 1971-1975. Bethesda, MD: U.S. Department of Health, Education, and Welfare, Public Health Service, National Institutes of Health; 1978.
52 Berenson GS. Cardiovascular risk factors in children. New York: Oxford University Press; 1980.
53 National Center for Health Statistics. Serum cholesterol levels of persons 4–74 years of age by socioeconomic characteristics: United States, 1971-74. Hyattsville, MD: U.S. Department of Health Education and Welfare, Public Health Service, National Center for Health Statistics; 1980.
54 Baker SG, Joffe BI, Mendelsohn D, Seftel HC. Treatment of homozygous familial hypercholesterolaemia with probucol. S Afr Med J. 1982;62(1):7-11. [pmid: 7089781].
55 Resnicow K, Morley-Kotchen J, Wynder E. Plasma cholesterol levels of 6585 children in the United States: results of the know your body screening in five states. Pediatrics. 1989;84(6):969-976. [pmid: 2587152].
56 Hickman TB, Briefel RR, Carrol MD, et al. Distributions and trends of serum lipid levels among United States children and adolescents ages 4–19 years: data from the third National Health and Nutrition Examination Survey. Prev Med. 1998;27:879-890. [pmid: 9922071].
57 Labarthe DR, Dai S, Fulton JE. Cholesterol screening in children: insights from Project HeartBeat! and NHANES III. Prog Pediatr Cardiol. 2003;17:169-178.
58 Kwiterovich PO Jr, Heiss G, Johnson N, Chase GA, Tamir I, Rifkind B. Assessment of plasma total cholesterol as a test to detect elevated low density (beta) lipoprotein cholesterol levels (type IIa hyperlipoproteinemia) in young subjects from a population-based sample. Am J Epidemiol. 1982;115(2):192-204. [pmid: 7058778].
59 Shea S, Basch CE, Irigoyen M, et al. Failure of family history to predict high blood cholesterol among Hispanic preschool children. Prev Med. 1990;19(4):443-455. [pmid: 2204914].
60 Dennison BA, Kikuchi DA, Srinivasan SR, Webber LS, Berenson GS. Serum total cholesterol screening for the detection of elevated low-density lipoprotein in children and adolescents: the Bogalusa Heart Study. Pediatrics. 1990;85(4):472-479. [pmid: 2314959].
61 Neufeld E. Personal communication to Dr. Elizabeth Haney about screening tests for children. Portland, OR; 2005.
62 Rifai N, Neufeld E, Ahlstrom P, Rimm E, D'Angelo L, Hicks JM. Failure of current guidelines for cholesterol screening in urban African-American adolescents. Pediatrics. 1996;98(3 Pt 1):383-388. [pmid: 8784361].
63 Gillman MW, Cupples LA, Moore LL, Ellison RC. Impact of within-person variability on identifying children with hypercholesterolemia: Framingham Children's Study. J Pediatr. 1992;121(3):342-347. [pmid: 1517906].
64 Harris N, Neufeld EJ, Newburger JW, et al. Analytical performance and clinical utility of a direct LDL-cholesterol assay in a hyperlipidemic pediatric population. Clin Chem. 1996;42(8 Pt 1):1182-1188. [pmid: 8697574].
65 Ticho BS, Neufeld EJ, Newburger JW, Harris N, Baker A, Rifai N. Utility of direct measurement of low-density lipoprotein cholesterol in dyslipidemic pediatric patients. Arch Pediatr Adol Med. 1998;152(8):787-791.
66 Couture P, Brun LD, Szots F, et al. Association of specific LDL receptor gene mutations with differential plasma lipoprotein response to simvastatin in young French Canadians with heterozygous familial hypercholesterolemia. Arterioscler Thromb Vasc Biol. 1998;18(6):1007-1012. [pmid: 9633944].
67 Davidson MH, Dugan LD, Burns JH, Sugimoto D, Story K, Drennan K. A psyllium-enriched cereal for the treatment of hypercholesterolemia in children: a controlled, double-blind, crossover study. Am J Clin Nutr. 1996;63(1):96-102. [pmid: 8604676].
68 de Jongh S, Lilien MR, op't Roodt J, Stroes ES, Bakker HD, Kastelein JJ. Early statin therapy restores endothelial function in children with familial hypercholesterolemia. J Am Coll Cardiol. 2002;40(12):2117-2121. [pmid: 12505222].
69 de Jongh S, Ose L, Szamosi T, et al. Efficacy and safety of statin therapy in children with familial hypercholesterolemia: a randomized, double-blind, placebo-controlled trial with simvastatin. Circulation. 2002;106(17):2231-2237. [pmid: 12390953].
70 de Jongh S, Kerckhoffs MC, Grootenhuis MA, Bakker HD, Heymans HS, Last BF. Quality of life, anxiety and concerns among statin-treated children with familial hypercholesterolaemia and their parents. Acta Paediatr. 2003;92(9):1096-1101. [pmid: 14599077].
71 Knipscheer HC, Boelen CC, Kastelein JJ, et al. Short-term efficacy and safety of pravastatin in 72 children with familial hypercholesterolemia. Pediatr Res. 1996;39(5):867-871. [pmid: 8726243].
72 Lambert M, Lupien PJ, Gagne C, et al. Treatment of familial hypercholesterolemia in children and adolescents: effect of lovastatin. Canadian Lovastatin in Children Study Group. Pediatrics. 1996;97(5):619-628. [pmid: 8628597].
73 Malloy MJ, Kane JP, Rowe JS. Familial hypercholesterolemia in children: treatment with p-aminosalicylic acid. Pediatrics. 1978;61(3):365-372. [pmid: 205828].
74 McCrindle BW, O'Neill MB, Cullen-Dean G, Helden E. Acceptability and compliance with two forms of cholestyramine in the treatment of hypercholesterolemia in children: a randomized, crossover trial. J Pediatr. 1997;130(2):266-273. [pmid: 9042130].
75 McCrindle BW, Helden E, Cullen-Dean G, Conner WT. A randomized crossover trial of combination pharmacologic therapy in children with familial hyperlipidemia. Pediatr Res. 2002;51(6):715-721. [pmid: 12032266].
76 McCrindle BW, Ose L, Marais AD. Efficacy and safety of atorvastatin in children and adolescents with familial hypercholesterolemia or severe hyperlipidemia: a multicenter, randomized, placebo-controlled trial. J Pediatr. 2003;143(1):74-80. [pmid: 12915827].
77 Stallings VA, Cortner JA, Shannon BM, et al. Preliminary report of a home-based education program for dietary treatment of hypercholesterolemia in children. Am J Health Promot. 1993;8(2):106-108. [pmid: 10146825].
78 Stein EA, Illingworth DR, Kwiterovich PO Jr, et al. Efficacy and safety of lovastatin in adolescent males with heterozygous familial hypercholesterolemia: a randomized controlled trial. JAMA. 1999;281(2):137-144. [pmid: 9917116].
79 Sveger T, Flodmark CE, Nordborg K, Nilsson-Ehle P, Borgfors N. Hereditary dyslipidemias and combined risk factors in children with a family history of premature coronary artery disease. Arch Dis Child. 2000;82(4):292-296. [pmid: 10735834].
80 Tonstad S, Sivertsen M, Aksnes L, Ose L. Low dose colestipol in adolescents with familial hypercholesterolaemia. Arch Dis Child. 1996;74(2):157-160. [pmid: 8660081].
81 Tonstad S, Knudtzon J, Sivertsen M, Refsum H, Ose L. Efficacy and safety of cholestyramine therapy in peripubertal and prepubertal children with familial hypercholesterolemia. J Pediatr. 1996;129(1):42-49. [pmid: 8757561].
82 Wheeler KA, West RJ, Lloyd JK, Barley J. Double blind trial of bezafibrate in familial hypercholesterolaemia. Arch Dis Child. 1985;60(1):34-37. [pmid: 3882058].
83 Wiegman A, de Groot E, Hutten BA. Arterial intima-media thickness in children heterozygous for familial hypercholesterolaemia. Lancet. 2004;363(9406):369-370. [pmid: 15070569].
84 Lombardi MP, Redeker EJ, Defesche JC, et al. Molecular genetic testing for familial hypercholesterolemia: spectrum of LDL receptor gene mutations in The Netherlands. Clin Genet. 2000;57(2):116-124. [pmid: 10735632].
85 Civeira F. International Panel on Management of Familial Hypercholesterolemia. Guidelines for the diagnosis and management of heterozygous familial hypercholesterolemia. Atherosclerosis. 2004;173(1):55-68. [pmid: 15177124].
86 Thorsson B, Sigurdsson G, Gudnason V. Systematic family screening for familial hypercholesterolemia in Iceland. Arterioscler Thromb Vasc Biol. 2003;23(2):335-338. [pmid: 12588780].
87 Kotze MJ, Langenhoven E, Theart L, Marx MP, Oosthuizen CJ. Report on a molecular diagnostic service for familial hypercholesterolemia in Afrikaners. Genet Couns. 1994;5(1):15-21. [pmid: 8031531].
88 Wiegman A, Rodenburg J, de Jongh S, et al. Family history and cardiovascular risk in familial hypercholesterolemia: data in more than 1000 children. Circulation. 2003;107(11):1473-1478. [pmid: 12654602].
89 Koivisto PV, Koivisto UM, Miettinen TA, Kontula K. Diagnosis of heterozygous familial hypercholesterolemia. DNA analysis complements clinical examination and analysis of serum lipid levels. Arterioscler & Thromb. 1992;12(5):584-592. [pmid: 1315570].
90 Laskarzewski PM, Khoury P, Kelly K, Mellies MJ, Morrison JA, Glueck CJ. Prevalence of familial hypertriglyceridemia: the Princeton School District Family Study. Prev Med. 1982;11(3):317-345. [pmid: 7111228].
91 Williams RR, Hunt SC, Schumacher MC, et al. Diagnosing heterozygous familial hypercholesterolemia using new practical criteria validated by molecular genetics. Am J Cardiol. 1993;72(2):171-176. [pmid: 8328379].
92 Bao W, Srinivasan SR, Wattigney WA, Berenson GS. Usefulness of childhood low-density lipoprotein cholesterol level in predicting adult dyslipidemia and other cardiovascular risks. The Bogalusa Heart Study. Arch Intern Med. 1996;156(12):1315-1320. [pmid: 8651840].
93 Berenson GS, Srinivasan SR, Frerichs RR, Webber LS. Serum high density lipoprotein and its relationship to cardiovascular disease risk factor variables in children—the Bogalusa heart study. Lipids. 1979;14(1):91-98. [pmid: 218070].
94 Clarke WR, HG S, Leaverton PE, Conner WE, Lauer RM. Tracking of blood lipids and blood pressures in school age children: the Muscatine study. Circulation. 1978;58(4):626-634. [pmid: 688572].
95 Lauer RM, Lee J, Clarke WR. Predicting adult cholesterol levels from measurements in childhood and adolescence: the Muscatine Study. Bull N Y Acad Med. 1989;65(10):1127-1142. discussion 1154–1160. [pmid: 2629967].
96 Stuhldreher WL, Orchard TJ, Donahue RP, Kuller LH, Gloninger MF, Drash AL. Cholesterol screening in childhood: sixteen-year Beaver County Lipid Study experience. J Pediatr. 1991;119(4):551-556. [pmid: 1919885].
97 Namboodiri KK, Green PP, Walden C, et al. The Collaborative Lipid Research Clinics Program Family Study. II. Response rates, representativeness of the sample, and stability of lipid and lipoprotein levels. Am J Epidemiol. 1984;119(6):944-958. [pmid: 6731433].
98 Laskarzewski P, Morrison JA, de Groot I, et al. Lipid and lipoprotein tracking in 108 children over a four year period. Pediatrics. 1979;64(5):584-591. [pmid: 226923].
99 Guo S, Beckett L, Chumlea WC, Roche AF, Siervogel RM. Serial analysis of plasma lipids and lipoproteins from individuals 9–21 y of age. Am J Clin Nutr. 1993;58(1):61-67. [pmid: 8317391].
100 Baumgartner RN, Guo S, Roche AF. Tracking of lipids and lipoproteins in adolescents from 12–22 years of age. The Fels longitudinal study. Ann N Y Acad Sci. 1991;623:406-409. [pmid: 2042849].
101 Twisk JW, Kemper HC, van Mechelen W, Post GB. Tracking of risk factors for coronary heart disease over a 14-year period: a comparison between lifestyle and biologic risk factors with data from the Amsterdam Growth and Health Study. Am J Epidemiol. 1997;145(10):888-898. [pmid: 9149660].
102 Mohler B, Ackermann-Liebrich U, Steffen T, Staehelin HB. Cholesterol screening in childhood: results of a 9-year follow-up study in Swiss and Italian children in Switzerland. Soz Praventivmed. 1996;41(6):333-340. [pmid: 9008838].
103 Vobecky JS, David P, Vobecky J. Dietary habits in relation to tracking of cholesterol level in young adolescents: a nine-year follow-up. Ann Nutr Metab. 1988;32(56):312-323. [pmid: 3254688].
104 Katzmarzyk PT, Perusse L, Malina RM, Bergeron J, Despres JP, Bouchard C. Stability of indicators of the metabolic syndrome from childhood and adolescence to young adulthood: the Quebec Family Study. J Clin Epidemiol. 2001;54(2):190-195. [pmid: 11166535].
105 Kallio MJ, Salmenpera L, Siimes MA, Perheentupa J, Miettinen TA. Tracking of serum cholesterol and lipoprotein levels from the first year of life. Pediatrics. 1993;91(5):949-954. [pmid: 8474815].
106 Bastida S, Sanchez-Muniz FJ, Cuena R, Perea S, Aragones A. High density lipoprotein-cholesterol changes in children with high cholesterol levels at birth. Eur J Pediatr. 2002;161(2):94-98. [pmid: 11954759].
107 Porkka KV, Viikari JS, Akerblom HK. Tracking of serum HDL-cholesterol and other lipids in children and adolescents: the Cardiovascular Risk in Young Finns Study. Prev Med. 1991;20(6):713-724. [pmid: 1766943].
108 Porkka KV, Viikari JS, Taimela S, Dahl M, Akerblom HK. Tracking and predictiveness of serum lipid and lipoprotein measurements in childhood: a 12-year follow-up. The Cardiovascular Risk in Young Finns study. Am J Epidemiol. 1994;140(12):1096-1110. [pmid: 7998592].
109 Fuentes RM, Notkola IL, Shemeikka S, Tuomilehto J, Nissinen A. Tracking of serum total cholesterol during childhood: an 8-year follow-up population-based family study in eastern Finland. Acta Paediatr. 2003;92(4):420-424. [pmid: 12801106].
110 Eisenmann JC, Welk GJ, Wickel EE, Blair SN. Aerobics Center Longitudinal S. Stability of variables associated with the metabolic syndrome from adolescence to adulthood: the Aerobics Center Longitudinal Study. Am J Hum Biol. 2004;16(6):690-696. [pmid: 15495227].
111 Nicklas TA, von Duvillard SP, Berenson GS. Tracking of serum lipids and lipoproteins from childhood to dyslipidemia in adults: the Bogalusa Heart Study. Int J Sports Med. 2002;23(Suppl 1):S39-43. [pmid: 12012261].
112 Orchard TJ, Donahue RP, Kuller LH, Hodge PN, Drash AL. Cholesterol screening in childhood: does it predict adult hypercholesterolemia? The Beaver County experience. J Pediatr. 1983;103(5):687-691. [pmid: 6631595].
113 Lauer RM, Clarke WR. Use of cholesterol measurements in childhood for the prediction of adult hypercholesterolemia. The Muscatine Study. JAMA. 1990;264(23):3034-3038. [pmid: 2243431].
114 Barnett AG, van der Pols JC, Dobson AJ. Regression to the mean: what it is and how to deal with it. Int J Epidemiol. 2004;34:215-220. [pmid: 15333621].
115 Bell MM, Joseph S. Screening 1140 fifth graders for hypercholesterolemia: family history inadequate to predict results. J Am Board Fam Pract. 1990;3(4):259-263. [pmid: 2248092].
116 Davidson DM, Van Camp J, Iftner CA, Landry SM, Bradley BJ, Wong ND. Family history fails to detect the majority of children with high capillary blood total cholesterol. J Sch Health. 1991;61(2):75-80. [pmid: 2016863].
117 Diller PM, Huster GA, Leach AD, Laskarzewski PM, Sprecher DL. Definition and application of the discretionary screening indicators according to the National Cholesterol Education Program for Children and Adolescents. J Pediatr. 1995;126(3):345-352. [pmid: 7869190].
118 Gagliano NJ, Emans SJ, Woods ER. Cholesterol screening in the adolescent. J Adolesc Health. 1993;14(2):104-108. [pmid: 8476872].
119 Griffin TC, Christoffel KK, Binns HJ, McGuire PA. Family history evaluation as a predictive screen for childhood hypercholesterolemia. Pediatric Practice Research Group. Pediatrics. 1989;84(2):365-373. [pmid: 2748269].
120 Muhonen LE, Burns TL, Nelson RP, Lauer RM. Coronary risk factors in adolescents related to their knowledge of familial coronary heart disease and hypercholesterolemia: the Muscatine Study. Pediatrics. 1994;93(3):444-451. [pmid: 8115204].
121 Primrose ED, Savage JM, Boreham CA, Cran GW, Strain JJ. Cholesterol screening and family history of vascular disease. Arch Dis Child. 1994;71(3):239-242. [pmid: 7979498].
122 Resnicow K, Cross D, Lacosse J, Nichols P. Evaluation of a school-site cardiovascular risk factor screening intervention. Prev Med. 1993;22(6):838-856. [pmid: 8115342].
123 Sanchez Bayle M, Gonzalez Vergaz A, Garcia Cuartero B, Santos Tapia M, Gonzalez Requejo A. Is a parental history of coronary arterial disease in children as discriminating as their lipoprotein profile? Nino Jesus Group. Int J Cardiol. 1992;36(3):267-271. [pmid: 1428260].
124 Steiner NJ, Neinstein LS, Pennbridge J. Hypercholesterolemia in adolescents: effectiveness of screening strategies based on selected risk factors. Pediatrics. 1991;88(2):269-275. [pmid: 1861925].
125 Troxler RG, Park MK, Miller MA, Karnavas BA, Lee DH. Predictive value of family history in detecting hypercholesterolemia in predominantly Hispanic adolescents. Tex Med. 1991;87(11):75-79. [pmid: 1759247].
126 Dennison BA, Kikuchi DA, Srinivasan SR, Webber LS, Berenson GS. Parental history of cardiovascular disease as an indication for screening for lipoprotein abnormalities in children. J Pediatr. 1989;115(2):186-194. [pmid: 2754548].
127 O'Loughlin J, Lauzon B, Paradis G, et al. Usefulness of the American Academy of Pediatrics recommendations for identifying youths with hypercholesterolemia. Pediatrics. 2004;113(6):1723-1727. [pmid: 15173497].
128 Wadowski SJ, Karp RJ, Murray-Bachmann R, Senft C. Family history of coronary artery disease and cholesterol: screening children in a disadvantaged inner-city population. Pediatrics. 1994;93(1):109-113. [pmid: 8265303].
129 Washington RL, Harrigan L, Day M. Early experience in treating hyperlipidemia in children. Ann N Y Acad Sci. 1991;623:434. [pmid: 2042859].
130 Lannon CM, Earp J. Parents' behavior and attitudes toward screening children for high serum cholesterol levels. Pediatrics. 7/7/04 1992;89(6 Pt 2):1159–1163.
131 Boulton TJ. The validity of screening for hypercholesterolaemia at different ages from 2 to 17 years. Aust N Z J Med. 1979;9(5):542-546. [pmid: 231425].
132 Williams RR, Hunt SC, Barlow GK, et al. Prevention of familial cardiovascular disease by screening for family history and lipids in youths. Clin Chem. 1992;38(8B Pt 2):1555-1560. [pmid: 1643739].
133 Dennison BA, Jenkins PL, Pearson TA. Challenges to implementing the current pediatric cholesterol screening guidelines into practice. Pediatrics. 1994;94(3):296-302. [pmid: 8065853].
134 Berenson GS, Srinivasan S. Cholesterol as a risk factor for early atherosclerosis: the Bogalusa Heart Study. Prog Pediatr Cardiol. 2003;17:113-122.
135 Andersen LB, Wedderkopp N, Hansen HS, Cooper AR, Froberg K. Biological cardiovascular risk factors cluster in Danish children and adolescents: the European Youth Heart Study. Prev Med. 2003;37(4):363-367. [pmid: 14507494].
136 Bergstrom E, Hernell O, Persson LA. Endurance running performance in relation to cardiovascular risk indicators in adolescents. Int J Sports Med. 1997;18(4):300-307. [pmid: 9231849].
137 Bonora E, Zenere M, Branzi P, et al. Influence of body fat and its regional localization on risk factors for atherosclerosis in young men. Am J Epidemiol. 1992;135(11):1271-1278. [pmid: 1626543].
138 Bonora E, Targher G, Branzi P, et al. Cardiovascular risk profile in 38-year and 18-year-old men. Contribution of body fat content and regional fat distribution. Int J Obes Relat Metab Disord. 1996;20(1):28-36. [pmid: 8788319].
139 Demerath E, Muratova V, Spangler E, Li J, Minor VE, Neal WA. School-based obesity screening in rural Appalachia. Prev Med. 2003;37(6 Pt 1):553-560. [pmid: 14636788].
140 DeStefano F, Berg RL, Griese GG Jr. Determinants of serum lipid and lipoprotein concentrations in children. Epidemiology. 1995;6(4):446-449. [pmid: 7548360].
141 Douglas MB, Birrer RB, Medidi S, Schlussel YR. Obese children should be screened for hypercholesterolemia. J Health Care Poor Underserved. 1996;7(1):24-35. [pmid: 8645782].
142 Durant RH, Linder CW, Jay S, Harkness JW, Gray RG. The influence of a family history of CHD risk factors on serum lipoprotein levels in black children and adolescents. J Adolesc Health Care. 1982;3(2):75-81. [pmid: 7141944].
143 Durant RH, Linder CW, Mahoney OM. Relationship between habitual physical activity and serum lipoprotein levels in white male adolescents. J Adolesc Health Care. 1983;4(4):235-240. [pmid: 6643201].
144 Durant RH, Baranowski T, Rhodes T, et al. Association among serum lipid and lipoprotein concentrations and physical activity, physical fitness, and body composition in young children. J Pediatr. 1993;123(2):185-192. [pmid: 8345412].
145 Dwyer T, Gibbons LE. The Australian Schools Health and Fitness Survey. Physical fitness related to blood pressure but not lipoproteins. Circulation. 1994;89(4):1539-1544. [pmid: 8149519].
146 Eisenmann JC, Malina RM. Age-related changes in subcutaneous adipose tissue of adolescent distance runners and association with blood lipoproteins. Ann Hum Biol. 2002;29(4):389-397. [pmid: 12160472].
147 Fripp RR, Hodgson JL, Kwiterovich PO, Werner JC, Schuler HG, Whitman V. Aerobic capacity, obesity, and atherosclerotic risk factors in male adolescents. Pediatrics. 1985;75(5):813-818. [pmid: 3991266].
148 Giovannini M, Bellu R, Ortisi MT, Incerti P, Riva E. Cholesterol and lipoprotein levels in Milanese children: relation to nutritional and familial factors. J Am Coll Nutr. 1992;11(Suppl):28S-31S. [pmid: 1619195].
149 Glassman MS, Schwarz SM. Cholesterol screening in children: should obesity be a risk factor?. J Am Coll Nutr. 1993;12(3):270-273. [pmid: 8409081].
150 Howard JK, Bindler RM, Dimico GS, et al. Cardiovascular risk factors in children: a Bloomsday research report. J of Pediatr Nurs. 1991;6(4):222-229. [pmid: 1865311].
151 Jarvisalo MJ, Jartti L, Nanto-Salonen K, et al. Increased Aortic Intima-Media Thickness: A Marker of Preclinical Atherosclerosis in High-Risk Children. Circulation. 2001;104(24):2943-2947. [pmid: 11739310].
152 Larsson B, Vaara I. Cholesterol screening of seven-year-old children. How to identify children at risk. Acta Paediatr. 1992;81(4):315-318. [pmid: 1606391].
153 Kunz F, Pechlaner C, Hortnagl H, Pfister R. The smoker's paradox and the real risk of smoking. Eur J Epidemiol. 2005;20(2):161-167. [pmid: 15792283].
154 Kwiterovich PO Jr, Barton BA, McMahon RP, et al. Effects of diet and sexual maturation on low-density lipoprotein cholesterol during puberty: the Dietary Intervention Study in Children (DISC). Circulation. 1997;96(8):2526-2533. [pmid: 9355889].
155 Macek M, Bell D, Rutenfranz J, et al. A comparison of coronary risk factors in groups of trained and untrained adolescents. Eur J Appl Physiol Occup Physiol. 1989;58(6):577-582. [pmid: 2786466].
156 Marti B, Vartiainen E. Relation between leisure time exercise and cardiovascular risk factors among 15-year-olds in eastern Finland. J Epidemiol Community Health. 1989;43(3):228-233. [pmid: 2607300].
157 Raitakari OT, Taimela S, Porkka KV, Viikari JS. Effect of leisure-time physical activity change on high-density lipoprotein cholesterol in adolescents and young adults. Ann Med. 1996;28(3):259-263. [pmid: 8811170].
158 Resnicow K, Futterman R, Vaughan RD. Body mass index as a predictor of systolic blood pressure in a multiracial sample of US schoolchildren. Ethn Dis. 1993;3(4):351-361. [pmid: 7888986].
159 Ribeiro JC, Guerra S, Oliveira J, et al. Physical activity and biological risk factors clustering in pediatric population. Prev Med. 2004;39(3):596-601. [pmid: 15313100].
160 Shear CL. The relationship between parental history of vascular disease and cardiovascular disease risk factors in children: the Bogalusa Heart Study. Am J Epidemiol. 1985;122(5):762-771. [pmid: 3876762].
161 Simon JA, Morrison JA, Similo SL, McMahon RP, Schreiber GB. Correlates of high-density lipoprotein cholesterol in Black girls and White girls: the NHLBI Growth and Health Study. Am J Pub Health. 1995;85(12):1698-1702. [pmid: 7503349].
162 Suter E, Hawes MR. Relationship of physical activity, body fat, diet, and blood lipid profile in youths 10–15 yr. Med Sci Sports Exerc. 1993;25(6):748-754. [pmid: 8321114].
163 Thorland WG, Gilliam TB. Comparison of serum lipids between habitually high and low active pre-adolescent males. Med Sci Sports Exerc. 1981;13(5):316-321. [pmid: 7321829].
164 Tolfrey K, Campbell IG, Jones AM. Selected predictor variables and the lipid-lipoprotein profile of prepubertal girls and boys. Med Sci Sports Exerc. 1999;31(11):1550-1557. [pmid: 10589856].
165 Tonstad S, Leren TP, Sivertsen M, Ose L. Determinants of lipid levels among children with heterozygous familial hypercholesterolemia in Norway. Arterioscler Thromb Vasc Biol. 1995;15(8):1009-1014. [pmid: 7627689].
166 Twisk JW, Kemper HC, Van Mechelen W, Post GB. Clustering of risk factors for coronary heart disease. the longitudinal relationship with lifestyle. Ann Epidemiol. 2001;11(3):157-165. [pmid: 11248580].
167 Twisk JW, Kemper HC, van Mechelen W, Post GB, van Lenthe FJ. Body fatness: longitudinal relationship of body mass index and the sum of skinfolds with other risk factors for coronary heart disease. Int J Obes Relat Metab Disord. 1998;22(9):915-922. [pmid: 9756252].
168 Twisk JW, Kemper HC, Mellenbergh GJ, van Mechelen W, Post GB. Relation between the longitudinal development of lipoprotein levels and lifestyle parameters during adolescence and young adulthood. Ann Epidemiol. 1996;6(3):246-256. [pmid: 8827160].
169 van Lenthe FJ, van Mechelen W, Kemper HC, Twisk JW. Association of a central pattern of body fat with blood pressure and lipoproteins from adolescence into adulthood. The Amsterdam Growth and Health Study. Am J Epidemiol. 1998;147(7):686-693. [pmid: 9554608].
170 van Stiphout WA, Hofman A, de Bruijn AM, Valkenburg HA. Distributions and determinants of total and high-density lipoprotein cholesterol in Dutch children and young adults. Prev Med. 1985;14(2):169-180. [pmid: 4048079].
171 Ward SD, Melin JR, Lloyd FP, Norton JA Jr, Christian JC. Determinants of plasma cholesterol in children—a family study. Am J Clin Nutr. 1980;33(1):63-70. [pmid: 7355782].
172 Wong ND, Hei TK, Qaqundah PY, Davidson DM, Bassin SL, Gold KV. Television viewing and pediatric hypercholesterolemia. Pediatrics. 1992;90(1 Pt 1):75-79. [pmid: 1614784].
173 Jiang X, Srinivasan SR, Webber LS, Wattigney WA, Berenson GS. Association of fasting insulin level with serum lipid and lipoprotein levels in children, adolescents, and young adults: the Bogalusa Heart Study. Arch Intern Med. 1995;155(2):190-196. [pmid: 7811129].
174 Gliksman MD, Lazarus R, Wilson A. Differences in serum lipids in Australian children: is diet responsible?. Int J Epidemiol. 1993;22(2):247-254. [pmid: 8505180].
175 Bachman RP, Schoen EJ, Stembridge A, Jurecki ER, Imagire RS. Compliance with childhood cholesterol screening among members of a prepaid health plan. Am J Dis Child. 1993;147(4):382-385. [pmid: 8456792].
176 Bistritzer T, Rosenzweig L, Barr J, et al. Lipid profile with paternal history of coronary heart disease before age 40. Arch Dis Child. 1995;73(1):62-65. [pmid: 7639553].
177 Davidson DM, Bradley BJ, Landry SM, Iftner CA, Bramblett SN. School-based blood cholesterol screening. J Pediatr Health Care. 1989;3(1):3-8. [pmid: 2492600].
178 Faigel HC. Screening college students for hypercholesterolemia. J Am Coll Health. 1992;40(6):272-275. [pmid: 1602094].
179 Garcia RE, Moodie DS. Routine cholesterol surveillance in childhood. Pediatrics. 1989;84(5):751-755. [pmid: 2640549].
180 Hammond J, Chinn S, Richardson H, Rona R. Response to venepuncture for monitoring in primary schools. Arch Dis Child. 1994;70(5):367-369. discussion 369–372. [pmid: 8017955].
181 Heyden S, Schneider KA, Roberts KF. Effectiveness of education-screening on cholesterol levels of students. Ann Nutr Metab. 1991;35(2):71-76. [pmid: 1872595].
182 Lansing AM, Barbie RN, Shaheen KA. Regional cholesterol screening: problems and potentials. J Ky Med Assoc. 1990;88(4):170-174. [pmid: 2110237].
183 Manchester RA, McDuffie C, Diamond E. Screening for hypercholesterolemia in college students. J Am Coll Health. 1989;37(4):149-153. [pmid: 2926025].
184 Polonsky SM, Bellet PS, Sprecher DL. Primary hyperlipidemia in a pediatric population: classification and effect of dietary treatment. Pediatrics. 1993;91(1):92-96. [pmid: 8416512].
185 Skovby F, Micic S, Jepsen B, et al. Screening for familial hypercholesterolaemia by measurement of apolipoproteins in capillary blood. Arch Dis Child. 1991;66(7):844-847. [pmid: 1863097].
186 Goff DC Jr, Donker GA, Ragan JD Jr, et al. Cholesterol screening in pediatric practice. Pediatrics. 1991;88(2):250-258. [pmid: 1861922].
187 Nader PR, Yang M, Luepker RV, et al. Parent and physician response to children's cholesterol values of 200 mg/dL or greater: the Child and Adolescent Trial for Cardiovascular Health Experiment. Pediatrics. 1997;99(5):E5. [pmid: 9113962].
188 Sinaiko AR, Prineas RJ. Reduction of cardiovascular disease: what is the role of the pediatrician?. Pediatrics. 1998;102(5):E61. [pmid: 9794991].
189 Bastida S, Perea S, Sanchez-Muniz FJ. Do neonates with high serum cholesterol levels have a different high density lipoprotein composition?. Eur J Pediatr. 1998;157(1):66-70. [pmid: 9461367].
190 Andersen GE, Lous P, Friis-Hansen B. Screening for hyperlipoproteinemia in 10,000 Danish newborns. Follow-up studies in 522 children with elevated cord serum VLDL-LDL-cholesterol. Acta Paediatr Scand. 1979;68(4):541-545. [pmid: 223372].
191 Kenny D, Ward OC, Mulhern B, Rashied AA. Failure of cord serum cholesterol and betalipoprotein as screening tests for familial hyperlipoproteinaemia. Ir J Med Sci. 1984;153(3):100-105. [pmid: 6724853].
192 Cress HR, Shaher RM, Greenberg MH, Laffin R. Lipoproteins in neonates. J Pediatr. 1974;84(4):585-587. [pmid: 4366188].
193 Barnes K, Nestel PJ, Pryke ES, Whyte HM. Neonatal plasma lipids. Med J Austr. 1972;2(18):1002-1005.
194 Andersen GE, Brokhattingen K, Lous P. Familial hypobetalipoproteinaemia in 9 children diagnosed as the result of cord blood screening for hypolipoproteinaemia in 10 000 Danish newborns. Arch Dis Child. 1979;54(9):691-694. [pmid: 229774].
195 Goldstein JL, Albers JJ, Schrott HG, Hazzard WR, Bierman EL, Motulsky AG. Plasma lipid levels and coronary heart disease in adult relatives of newborns with normal and elevated cord blood lipids. Am J Hum Genet. 1974;26(6):727-735. [pmid: 4440681].
196 Darmady JM, Fosbrooke AS, Lloyd JK. Prospective study of serum cholesterol levels during first year of life. Br Med J. 1972;2(815):685-688. [pmid: 5067674].
197 Tsang RC, Fallat RW, Glueck CJ. Cholesterol at birth and age 1: comparison of normal and hypercholesterolemic neonates. Pediatrics. 1974;53(4):458-470. [pmid: 4362901].
198 Kwiterovich PO Jr, Levy RI, Fredrickson DS. Neonatal diagnosis of familial type-II hyperlipoproteinaemia. Lancet. 1973;1(7795):118-121. [pmid: 4118465].
199 Andersen GE, Nielsen HG. Neonatal screening for hyperlipoproteinemia. Methods for direct estimation of cord serum VLDL + LDL. Clin Chim Acta. 1976;66(1):29-41. [pmid: 177231].
200 Van Biervliet JP, Vercaemst R, De Keersgieter W, Vinaimont N, Caster H, Rosseneu M. Evolution of lipoprotein patterns in newborns. Acta Paediatr Scand. 1980;69(5):593-596. [pmid: 7234379].
201 Brewster TG, Waite DJ, Hudson GA. Quantitation of beta-lipoprotein in cord serum by rate nephelometric immunoassay: a potential screening test for familial hypercholesterolemia. Clin Chem. 1982;28(5):1192-1196. [pmid: 7074903].
202 Wood WG, Schumacher M, Weigert S. (Apo)lipoprotein(a) concentrations at birth and in the first days and months of life—studies on the distribution of serum levels and the predictive value of measurements made at this time. Eur J Clin Chem Clin Biochem. 1995;33(3):139-145. [pmid: 7605826].
203 Vladutiu GD, Glueck CJ, Schultz MT, McNeely S, Guthrie R. beta-Lipoprotein quantitation in cord blood spotted on filter paper: a screening test. Clin Chem. 1980;26(9):1285-1290. [pmid: 7398043].
204 Wilcken DE, Blades BL, Dudman NP. A neonatal screening approach to the detection of familial hypercholesterolaemia and family-based coronary prevention. J Inherit Metab Dis. 1988;11(Suppl 1):87-90. [pmid: 3141689].
205 Blades BL, Dudman NP, Wilcken DE. Screening for familial hypercholesterolemia in 5000 neonates: a recall study. Pediatr Res. 1988;23(5):500-504. [pmid: 3387172].
206 Bangert SK, Eldridge PH, Peters TJ. Neonatal screening for familial hypercholesterolaemia by immunoturbidimetric assay of apolipoprotein B in dried blood spots. Clin Chim Acta. 1992;213(13):95-101. [pmid: 1477991].
207 Van Biervliet JP, Vinaimont N, Caster H, Rosseneu M, Belpaire F. A screening procedure for dyslipoproteinemia in the newborn. Apoprotein quantitation on dried blood spots. Clin Chim Acta. 1982;120(2):191-200. [pmid: 7067144].
208 Roseneu M, Van Biervliet JP. Screening and follow-up of infants with dyslipoproteinemia. Prog Clin Biol Res. 1985;188:79-86. [pmid: 3933016].
209 Beeso J, Wong N, Ayling R, et al. Screening for hypercholesterolaemia in 10,000 neonates in a multi-ethnic population. Eur J Pediatr. 1999;158(10):833-837. [pmid: 10486088].
210 Vuorio AF, Turtola H, Kontula K. Neonatal diagnosis of familial hypercholesterolemia in newborns born to a parent with a molecularly defined heterozygous familial hypercholesterolemia. Arterioscler Thromb Vasc Biol. 1997;17(11):3332-3337. [pmid: 9409330].
211 Croyle RT, Sun YC, Louie DH. Psychological minimization of cholesterol test results: moderators of appraisal in college students and community residents. Health Psychol. 1993;12(6):503-507. [pmid: 8293735].
212 McHale SM, Tershakovec AM, Corneal DA, Tournier BA, Shannon BM. Psychosocial factors in nutrition education for hypercholesterolemic children. Ann Behav Med. 1998;20(3):233-240. [pmid: 9989332].
213 Rosenberg E, Lamping DL, Joseph L, Pless IB, Franco ED. Cholesterol screening of children at high risk: behavioural and psychological effects. Can Med Assoc J. 1997;156(4):489-496. [pmid: 9054818].
214 Tonstad S. Familial hypercholesterolaemia: a pilot study of parents' and children's concerns. Acta Paediatr. 1996;85(11):1307-1313. [pmid: 8955457].
215 Rosenthal SL, Knauer-Black S, Stahl MP, Catalanotto TJ, Sprecher DL. The psychological functioning of children with hypercholesterolemia and their families. A preliminary investigation. Clinical Pediatrics. 1993;32(3):135-141. [pmid: 8453828].
216 Hanna KJ, Ewart CK, Kwiterovich PO Jr. Child problem solving competence, behavioral adjustment and adherence to lipid-lowering diet. Patient Educ Couns. 1990;16(2):119-131. [pmid: 2290766].
217 Epstein LH, Kuller LH, Wing RR, Valoski A, McCurley J. The effect of weight control on lipid changes in obese children. Am J Dis Child. 1989;143(4):454-457. [pmid: 2929526].
218 Obarzanek E, Kimm SY, Barton BA, et al. Long-term safety and efficacy of a cholesterol-lowering diet in children with elevated low-density lipoprotein cholesterol: seven-year results of the Dietary Intervention Study in Children (DISC). Pediatrics. 2001;107(2):256-264. [pmid: 11158455].
219 DISC Collaborative Research Group. Efficacy and safety of lowering dietary intake of fat and cholesterol in children with elevated low-density lipoprotein cholesterol. The Dietary Intervention Study in Children (DISC). The Writing Group for the DISC Collaborative Research Group. JAMA. 1995;273(18):1429-1435. [pmid: 7723156].
220 Shannon BM, Tershakovec AM, Martel JK, Achterberg CL, Cortner JA. Reduction of elevated LDL-cholesterol levels of 4- to 10-year-old children through home-based dietary education. Pediatrics. 1994;94(6):923-927. [pmid: 7971012].
221 Becque MD, Katch VL, Rocchini AP, Marks CR, Moorehead C. Coronary risk incidence of obese adolescents: reduction by exercise plus diet intervention. Pediatrics. 1988;81(5):605-612. [pmid: 3357722].
222 Walter HJ, Hofman A, Connelly PA, Barrett LT, Kost KL. Primary prevention of chronic disease in childhood: changes in risk factors after one year of intervention. Am J Epidemiol. 1985;122(5):772-781. [pmid: 4050769].
223 Dennison BA, Levine DM. Randomized, double-blind, placebo-controlled, two-period crossover clinical trial of psyllium fiber in children with hypercholesterolemia. J Pediatr. 1993;123(1):24-29. [pmid: 8391569].
224 Engler MM, Engler MB, Malloy MJ, et al. Antioxidant vitamins C and E improve endothelial function in children with hyperlipidemia: Endothelial Assessment of Risk from Lipids in Youth (EARLY) Trial. Circulation. 2003;108(9):1059-1063. [pmid: 12912807].
225 Ferguson MA, Gutin B, Le NA, et al. Effects of exercise training and its cessation on components of the insulin resistance syndrome in obese children. Int J Obes Relat Metab Disord. 1999;23(8):889-895. [pmid: 10490792].
226 Kang HS, Gutin B, Barbeau P, et al. Physical training improves insulin resistance syndrome markers in obese adolescents. Med Sci Sports Exerc. 2002;34(12):1920-1927. [pmid: 12471297].
227 Kuehl KS, Cockerham JT, Hitchings M, Slater D, Nixon G, Rifai N. Effective control of hypercholesterolemia in children with dietary interventions based in pediatric practice. Prev Med. 1993;22(2):154-166. [pmid: 8483855].
228 Stergioulas A, Tripolitsioti A, Messinis D, Bouloukos A, Nounopoulos C. The effects of endurance training on selected coronary risk factors in children. Acta Paediatr. 1998;87(4):401-404. [pmid: 9628295].
229 Williams CL, Bollella M, Spark A, Puder D. Soluble fiber enhances the hypocholesterolemic effect of the step I diet in childhood. J Am Coll Nutr. 1995;14(3):251-257. [pmid: 8586774].
230 Boreham CA, Wallace WF, Nevill A. Training effects of accumulated daily stair-climbing exercise in previously sedentary young women. Prev Med. 2000;30(4):277-281. [pmid: 10731455].
231 Gold K, Wong N, Tong A, et al. Serum apolipoprotein and lipid profile effects of an oat-bran-supplemented, low-fat diet in children with elevated serum cholesterol. Ann N Y Acad Sci. 1991;623:429-431. [pmid: 2042857].
232 Linder CW, DuRant RH, Mahoney OM. The effect of physical conditioning on serum lipids and lipoproteins in white male adolescents. Med Sci Sports Exerc. 1983;15(3):232-236. [pmid: 6353127].
233 Savage MP, Petratis MM, Thomson WH, Berg K, Smith JL, Sady SP. Exercise training effects on serum lipids of prepubescent boys and adult men. Med Sci Sports Exerc. 1986;18(2):197-204. [pmid: 3702647].
234 Engler MM, Engler MB, Malloy M, et al. Docosahexaenoic acid restores endothelial function in children with hyperlipidemia: results from the EARLY study. Int J Clin Pharmacol Ther. 2004;42(12):672-679. [pmid: 15624283].
235 McCrindle BW, Helden E, Conner WT. Garlic extract therapy in children with hypercholesterolemia. Arch Pediatr Adolesc Med. 1998;152(11):1089-1094. [pmid: 9811286].
236 Engler MM, Engler MB, Malloy MJ, Paul SM, Kulkarni KR, Mietus-Snyder ML. Effect of docosahexaenoic acid on lipoprotein subclasses in hyperlipidemic children (the EARLY study). Am J Cardiol. 2005;95(7):869-871. [pmid: 15781019].
237 Fernandes J, Dijkhuis-Stoffelsma R, Groot PH, Grose WF, Ambagtsheer JJ. The effect of a virtually cholesterol-free, high-linoleic-acid vegetarian diet on serum lipoproteins of children with familial hypercholesterolemia (type II-A). Acta Paediatr Scand. 1981;70(5):677-682. [pmid: 7324917].
238 Tonstad S, Refsum H, Sivertsen M, Christophersen B, Ose L, Ueland PM. Relation of total homocysteine and lipid levels in children to premature cardiovascular death in male relatives. Pediatr Res. 1996;40(1):47-52. [pmid: 8798245].
239 Glueck CJ, McGill HC Jr, Shank RE, Lauer RM. American Heart Association Committee Report. Value and safety of diet modification to control hyperlipidemia in childhood and adolescence. Circulation. 1978;58:381A-390. [pmid: 354820].
240 Hedman M, Neuvonen PJ, Neuvonen M, Antikainen M. Pharmacokinetics and pharmacodynamics of pravastatin in children with familial hypercholesterolemia. Clin Pharmacol Ther. 2003;74(2):178-185. [pmid: 12891228].
241 Dirisamer A, Hachemian N, Bucek RA, Wolf F, Reiter M, Widhalm K. The effect of low-dose simvastatin in children with familial hypercholesterolaemia: a 1-year observation. Eur J Pediatr. 2003;162(6):421-425. [pmid: 12756561].
242 Sinzinger H, O'Grady J. Professional athletes suffering from familial hypercholesterolaemia rarely tolerate statin treatment because of muscular problems. Br J Clin Pharmacol. 2004;57(4):525-528. [pmid: 15025753].
243 Ducobu J, Brasseur D, Chaudron JM, et al. Simvastatin use in children. Lancet. 1992;339(8807):1488. [pmid: 1351171].
244 Stefanutti C, Lucani G, Vivenzio A, Di Giacomo S. Diet only and diet plus simvastatin in the treatment of heterozygous familial hypercholesterolemia in childhood. Drugs Exp Clin Res. 1999;25(1):23-28. [pmid: 10337501].
245 Curtis DM, Driscoll DJ, Goldman DH, Weidman WH. Loss of dental enamel in a patient taking cholestyramine. Mayo Clin Proc. 1991;66(11):1131. [pmid: 1943246].
246 Farah JR, Kwiterovich PO, Neill CA. A study of the dose-effect relationship of cholestyramine in children with familial hypercholesterolemia. Adv Exp Med Biol. 1977;82:212-215. [pmid: 200092].
247 Farah JR, Kwiterovich PO Jr, Neill CA. Dose-effect relation of cholestryamine in children and young adults with familial hypercholesterolaemia. Lancet. 1977;1(8002):59-63. [pmid: 63709].
248 Groot PH, Dijkhuis-Stoffelsma R, Grose WF, Ambagtsheer JJ, Fernandes J. The effects of colestipol hydrochloride on serum lipoprotein lipid and apolipoprotein B and A-I concentrations in children heterozygous for familial hypercholesterolemia. Acta Paediatr Scand. 1983;72(1):81-85. [pmid: 6407278].
249 Hansen D, Michaelsen KF, Skovby F. Growth during treatment of familial hypercholesterolemia. Acta Paediatr. 1992;81(12):1023-1025. [pmid: 1290846].
250 Harvengt C, Desager JP. Colestipol in familial type II hyperlipoproteinemia: a three-year trial. Clin Pharmacol Ther. 1976;20(3):310-314. [pmid: 182429].
251 Koletzko B, Kupke I, Wendel U. Treatment of hypercholesterolemia in children and adolescents. Acta Paediatr. 1992;81(9):682-685. [pmid: 1421908].
252 Liacouras CA, Coates PM, Gallagher PR, Cortner JA. Use of cholestyramine in the treatment of children with familial combined hyperlipidemia. J Pediatr. 1993;122(3):477-482. [pmid: 8441109].
253 Schwarz KB, Goldstein PD, Witztum JL, Schonfeld G. Fat-soluble vitamin concentrations in hypercholesterolemic children treated with colestipol. Pediatrics. 1980;65(2):243-250. [pmid: 7354970].
254 Tonstad S, Ose L. Colestipol tablets in adolescents with familial hypercholesterolaemia. Acta Paediatr. 1996;85(9):1080-1082. [pmid: 8888922].
255 Tonstad S, Refsum H, Ose L, Ueland PM. The C677T mutation in the methylenetetrahydrofolate reductase gene predisposes to hyperhomocysteinemia in children with familial hypercholesterolemia treated with cholestyramine. J Pediatr. 1998;132(2):365-368. [pmid: 9506661].
256 West RJ, Lloyd JK. Use of cholestyramine in treatment of children with familial hypercholesterolaemia. Arch Dis Child. 1973;48(5):370-374. [pmid: 4703066].
257 West RJ, Lloyd JK. The effect of cholestyramine on intestinal absorption. Gut. 1975;16(2):93-98. [pmid: 1168607].
258 West RJ, Fosbrooke AS, Lloyd JK. Treatment of children with familial hypercholesterolaemia. Postgrad Med J. 1975;51(8):suppl 82–87.
259 West RJ, Lloyd JK, Leonard JV. Long-term follow-up of children with familial hypercholesterolaemia treated with cholestyramine. Lancet. 1980;2(8200):873-875. [pmid: 6107543].
260 Glueck CJ, Tsang RC, Fallat RW, Mellies M. Therapy of familial hypercholesterolemia in childhood: diet and cholestyramine resin for 24 to 36 months. Pediatrics. 1977;59(3):433-441. [pmid: 840563].
261 Glueck CJ, Mellies MJ, Dine M, Perry T, Laskarzewski P. Safety and efficacy of long-term diet and diet plus bile acid-binding resin cholesterol-lowering therapy in 73 children heterozygous for familial hypercholesterolemia.[retraction in Glueck CJ, Laskarzewski P, Meelies MJ, Perry T. Pediatrics 1987 Nov;80(5):766]. Pediatrics. 1986;78(2):338-348. [pmid: 3526270].
262 Glueck CJ, Tsang RC, Fallat RW, Scheel D. Plasma vitamin A and E levels in children with familial type II hyperlipoproteinemia during therapy with diet and cholestyramine resin. Pediatrics. 1974;54(1):51-55. [pmid: 4365953].
263 Glueck CJ, Fallat R, Tsang R. Pediatric familial type II hyperlipoproteinemia: therapy with diet and cholestyramine resin. Pediatrics. 1973;52(5):669-679. [pmid: 4355362].
264 Becker M, Staab D, Von Bergman K. Long-term treatment of severe familial hypercholesterolemia in children: effect of sitosterol and bezafibrate. Pediatrics. 1992;89(1):138-142. [pmid: 1727999].
265 Brun LD, Gagne C, Coulombe P, Lupien PJ, Dussault JH, Moorjani S. Effects of dextrothyroxine on the pituitary-thyroid axis in hypercholesterolemic children and goitrous adults. J Clin Endocrinol Metab. 1980;51(6):1306-1310. [pmid: 6777394].
266 Colletti RB, Neufeld EJ, Roff NK, McAuliffe TL, Baker AL, Newburger JW. Niacin treatment of hypercholesterolemia in children. Pediatrics. 1993;92(1):78-82. [pmid: 8516088].
267 McDuffie JR, Calis KA, Uwaifo GI, et al. Three-month tolerability of orlistat in adolescents with obesity-related comorbid conditions. Obes Res. 2002;10(7):642-650. [pmid: 12105286].
268 Stein EA. Treatment of familial hypercholesterolemia with drugs in children. Arteriosclerosis. 1989;9(1 Suppl):I145-151. [pmid: 2912428].
269 Steinmetz J, Morin C, Panek E, Siest G, Drouin P. Biological variations in hyperlipidemic children and adolescents treated with fenofibrate. Clin Chim Acta. 1981;112(1):43-53. [pmid: 6113065].
270 Copperman N, Schebendach J, Arden MR, Jacobson MS. Nutrient quality of fat- and cholesterol-modified diets of children with hyperlipidemia. Arch Pediatr Adol Med. 1995;149(3):333-336.
271 Tonstad S, Novik TS, Vandvik IH. Psychosocial function during treatment for familial hypercholesterolemia. Pediatrics. 1996;98(2 Pt 1):249-255. [pmid: 8692626].
272 Segall MM, Tamir I, Fosbrooke AS, Lloyd JK, Wolff OH. Effects of short-term high-carbohydrate feeding on serum triglyceride of children with familial hypercholesterolaemia. Arch Dis Child. 1970;45(241):393-398. [pmid: 5427855].
273 Witschi JC, Singer M, Wu-Lee M, Stare FJ. Family cooperation and effectiveness in a cholesterol-lowering diet. J Am Diet Assoc. 1978;72(4):384-389. [pmid: 641273].
274 McKenzie J, Dixon LB, Smiciklas-Wright H, Mitchell D, Shannon B, Tershakovec A. Change in nutrient intakes, number of servings, and contributions of total fat from food groups in 4- to 10-year-old children enrolled in a nutrition education study. J Am Diet Assoc. 1996;96(9):865-873. [pmid: 8784330].
275 Moreno LA, Sarria A, Lazaro A, Lasierra MP, Larrad L, Bueno M. Lymphocyte T subset counts in children with hypercholesterolemia receiving dietary therapy. Ann Nutr Metab. 1998;42(5):261-265. [pmid: 9812016].
276 Sanchez-Bayle M, Gonzalez-Requejo A, Baeza J, et al. Diet therapy for hypercholesterolemia in children and adolescents. A follow-up. Arch Pediatr Adol Med. 1994;148(1):28-32.
277 Rose V, Allen DM, Pearse RG, Chapell J. Primary hyperlipoproteinemia in childhood and adolescence: identification and treatment of persons at risk for premature atherosclerosis. Can Med Assoc J. 1976;115(8):753-756. 779. [pmid: 184909].
278 Lifshitz F, Moses N. Growth failure. A complication of dietary treatment of hypercholesterolemia. Am J Dis Child. 1989;143(5):537-542. [pmid: 2718985].
279 Cetta F, Driscoll DJ, Lucas AR, et al. Growth patterns of hyperlipidemic children enrolled in a preventive cardiovascular health clinic. Clinical Pediatrics. 1994;33(10):588-592. [pmid: 7813137].
280 Jacobson MS, Tomopoulos S, Williams CL, Arden MR, Deckelbaum RJ, Starc TJ. Normal growth in high-risk hyperlipidemic children and adolescents with dietary intervention. Prev Med. 1998;27(6):775-780. [pmid: 9922057].
281 Lavigne JV, Brown KM, Gidding S, et al. A cholesterol-lowering diet does not produce adverse psychological effects in children: three-year results from the dietary intervention study in children. Health Psychol. 1999;18(6):604-613. [pmid: 10619534].
282 Feoli-Fonseca JC, Levy E, Godard M, Lambert M. Familial lipoprotein lipase deficiency in infancy: clinical, biochemical, and molecular study. J Pediatr. 1998;133(3):417-423. [pmid: 9738727].
283 Sanchez-Bayle M, Soriano-Guillen L. Influence of dietary intervention on growth in children with hypercholesterolaemia. Acta Paediatr. 2003;92(9):1043-1046. [pmid: 14599067].
284 Tershakovec AM, Jawad AF, Stallings VA, et al. Growth of hypercholesterolemic children completing physician-initiated low-fat dietary intervention. J Pediatr. 1998;133(1):28-34. [pmid: 9672506].
285 Kaistha A, Deckelbaum RJ, Starc TJ, Couch SC. Overrestriction of dietary fat intake before formal nutritional counseling in children with hyperlipidemia. Arch Pediatr Adol Med. 2001;155(11):1225-1230.
286 Pugliese MT, et al. Parental health beliefs: a cause of non-organic failure to thrive. Pediatrics. 1987;80(2):175-181. [pmid: 3615087].
287 Amundsen AL, Ntanios F, Put N, Ose L. Long-term compliance and changes in plasma lipids, plant sterols and carotenoids in children and parents with FH consuming plant sterol ester-enriched spread. Eur J Clin Nutr. 2004;58(12):1612-1620. [pmid: 15199384].
288 Becker M, Staab D, Von Bergmann K. Treatment of severe familial hypercholesterolemia in childhood with sitosterol and sitostanol. J Pediatr. 1993;122(2):292-296. [pmid: 8429449].
289 Clarke JT, Cullen-Dean G, Regelink E, Chan L, Rose V. Increased incidence of epistaxis in adolescents with familial hypercholesterolemia treated with fish oil. J Pediatr. 1990;116(1):139-141. [pmid: 2295954].
290 Glassman M, Spark A, Berezin S, Schwartz S, Medow M, Newman LJ. Treatment of type IIa hyperlipidemia in childhood by a simplified American Heart Association diet and fiber supplementation. Am J Dis Child. 1990;144:973-976. [pmid: 2168676].
291 Gulesserian T, Widhalm K. Effect of a rapeseed oil substituting diet on serum lipids and lipoproteins in children and adolescents with familial hypercholesterolemia. J Am Coll Nutr. 2002;21(2):103-108. [pmid: 11999536].
292 Mietus-Snyder M, Malloy MJ. Endothelial dysfunction occurs in children with two genetic hyperlipidemias: improvement with antioxidant vitamin therapy. J Pediatr. 1998;133(1):35-40. [pmid: 9672507].
293 Sanchez-Bayle M, Gonzalez-Requejo A, Asensio-Anton J, Ruiz-Jarabo C, Fernandez-Ruiz ML, Baeza J. The effect of fiber supplementation on lipid profile in children with hypercholesterolemia. Clinical Pediatrics. 2001;40(5):291-294. [pmid: 11388682].
294 Laurin D, Jacques H, Moorjani S, et al. Effects of a soy-protein beverage on plasma lipoproteins in children with familial hypercholesterolemia. Am J Clin Nutr. 1991;54(1):98-103. [pmid: 2058593].
295 Schlierf G, Oster P, Heuck CC, Raetzer H, Schellenberg B. Sitosterol in juvenile type II hyperlipoproteinemia. Atherosclerosis. 1978;30(4):245-248. [pmid: 213081].
296 Zavoral JH, Hannan P, Fields DJ, et al. The hypolipidemic effect of locust bean gum food products in familial hypercholesterolemic adults and children. Am J Clin Nutr. 1983;38(2):285-294. [pmid: 6308996].
297 Tolfrey K, Campbell IG, Batterham AM. Exercise training induced alterations in prepubertal children's lipid-lipoprotein profile. Med Sci Sports Exerc. 1998;30(12):1684-1692. [pmid: 9861600].
298 Kavey RE, Kveselis DA, Gaum WE. Valvular and Pediatric Congenital Heart Disease. Am Heart J. 1997;133(2).
299 Tershakovec AM, Brannon SD, Bennett MJ, Shannon BM. The cost of implementation of the Clinical Laboratory Improvement Amendments of 1988—the example of pediatric office-based cholesterol screening. Pediatrics. 1995;96(2 Pt 1):230-234. [pmid: 7630675].
300 McKenney JM. An evaluation of cholesterol screening in community pharmacies. Am Pharm. 1993;NS33(7):34-40. [pmid: 8342493].
301 Marks D, Wonderling D, Thorogood M, Lambert H, Humphries SE, Neil HA. Cost effectiveness analysis of different approaches of screening for familial hypercholesterolaemia. BMJ. 2002;324(7349):1303. [pmid: 12039822].
302 Iannuzzi A, Licenziati MR, Acampora C, et al. Increased carotid intima-media thickness and stiffness in obese children. Diabetes Care. 2004;27(10):2506-2508. [pmid: 15451928].
303 Jarvisalo MJ, Lehtimaki T, Raitakari O. Determinants of arterial nitrate-mediated dilation in children: role of oxidized low-density lipoprotein, endothelial function, and carotid intima-media thickness. Circulation. 2004;109(23):2885-2889. [pmid: 15159289].
304 Davis PH, Dawson JD, Riley WA, Lauer RM. Carotid intimal-medial thickness is related to cardiovascular risk factors measured from childhood through middle age: the Muscatine Study. Circulation. 2001;104(23):2815-2819. [pmid: 11733400].
305 Rodenburg J, Vissers MN, Wiegman A, Trip MD, Bakker HD, Kastelein JJ. Familial hypercholesterolemia in children. Curr Opin Lipidol. 2004;15(4):405-411. [pmid: 15243213].
306 Lavin A, Nauss AH, Newburger JW. A survey of pediatric management of dyslipidemias in New England. Pediatr Cardiol. 1992;13(2):76-79. [pmid: 1614923].