# Discussion

## Conclusions

A summary of the evidence included in this review is presented in Table 18. Overall, there was inadequate evidence to address key questions about efficacy of screening children and adolescents for dyslipidemia for delaying the onset and reducing the incidence of CHD-related events, effectiveness of treatments (drug, diet, exercise and combination) on reducing incidence of adult dyslipidemia or delaying the onset and reducing the risk of CHD-related events, whether improving dyslipidemia in children and adolescents reduces the risk of adult dyslipidemia, and cost-effectiveness of screening for dyslipidemia in children and adolescents.

Table 18 Summary of Systematic Evidence Review

Arrow | Key question | Level and Type of Evidence | Quality of Evidence | Conclusions
1 | Is screening for dyslipidemia in children effective in delaying the onset and reducing the incidence of CHD-related events? | None
2 | What is the accuracy of screening for dyslipidemia in identifying children at increased risk of CHD-related events and other outcomes? | | | See below.
2a | What are abnormal lipid values in children? | II-2 | Fair to Poor | Normal values for lipids in children are currently defined according to population levels (percentiles). NCEP recommendations are based on LRC data, which defines the 95th percentile for TC as 200 mg/dL and for LDL as 130 mg/dL. There are more recent studies suggesting that age, gender, racial differences and temporal trends shift these cut points. The NCEP has defined levels of LDL for which drug treatment (LDL≥190mg/dL or LDL≥160mg/dL with family history of early CHD), further evaluation, diet therapy and testing (LDL>130mg/dL) and diet therapy with increased surveillance (LDL110–129mg/dL) are recommended.
2b | What are the appropriate tests? How well do screening tests (non-fasting total cholesterol, fasting total cholesterol, fasting lipid panel) identify individuals with dyslipidemia? | II-2, II-3. | Poor | The most appropriate test is one that accurately predicts future risk and benefit from treatment. In the general population of children there have not been adequate studies to determine these characteristics. Data from few studies suggest that TC above the 95th percentile predicts LDL above the 95th percentile with 44–69% sensitivity. TC minus HDL might be a more sentivitive test, but has not been extensively evaluated. A single TC measurement is inadequate to classify children and adolescents into NCEP risk categories with 95% confidence.
2c | How well do lipid levels track from childhood to adulthood? | II-2. Longitudinal cohort studies. | Good | Serial correlations measured in individual children over time are higher for TC (r=0.38–0.78) and LDL (r=0.4–0.7) than for HDL and TG. Approximately 40–55% of children with elevated lipids (by percentile) will continue to have elevated lipids on follow-up as older children. In two studies that followed children/adolescents to young adulthood (between ages 20–30), 40–45% continued to have elevated lipids.
2d | What is the accuracy of family history in determining risk? | II-2. Studies of diagnostic test accuracy. | Good | Multiple good quality studies evaluating the use of family history as a diagnostic test for dyslipidemia in children using varied and large populations demonstrate that family history is an imperfect screening tool for detecting dyslipidemia among children.
2f | What are other important risk factors? | II-2. Cross-sectional and longitudinal cohort studies. | Good for family history; Good for obesity; Poor for all other risk factors. | Evidence from epidemiologic cross-sectional and cohort studies establish a statistical association between family history and overweight and elevations in lipids. There is inadequate evidence to show the magnitude of the effect of overweight on lipids, or the impact that incorporating weight measures into a screening tool could have. Multiple other risk factors (diet, physical inactivity, aerobic capacity/fitness, puberty level and smoking) have not been evaluated adequately to assess their contribution to dyslipidemia in children or their usefulness as screening tools.
2e | What are effective screening strategies for children (including frequency of testing, optimal age for testing)? | I, III. One RCT and multiple descriptive studies of screening programs. | Poor | Currently recommended screening strategies have limited diagnostic accuracy, low adherence to guidelines by providers, and limited compliance by parents and children. No trials compare strategies of screening in children. No studies address the frequency and optimal age for testing.
3 | What are the adverse effects of screening including false positives, false negatives, labeling, etc? | I, II-3, III. | Fair | Studies demonstrate lack of parental compliance with screening and follow-up recommendations. Reasons for non-compliance include concern about test accuracy, lack of proof that intervention makes a difference in children, concern about upseting the child, refusal by the child, inconvenience, or decision to institute a diet themselves and have child rechecked subsequently.
4 | In children and adolescents, what is the effectiveness of drug, diet, exercise, and combination therapy in reducing the incidence of adult dyslipidemia, and delaying the onset and reducing the incidence of CHD-related events and other outcomes (including optimal age for initiation of treatment)? | None
5–8 | What is the effectiveness of drug, diet, exercise, and combination therapy for treating dyslipidemia in children/adolescents (including the incremental benefit of treating dyslipidemia in childhood)? | I. RCTs in familial hypercholesterolemia patients (drugs and diet) and general populations of children (diet and exercise) | Good quality studies with fair external validity for drug therapy. Fair to poor for diet and exercise treatments. | Statins are effective for reducing TC and LDL in children with familial hypercholesterolemia. It is not clear how this efficacy translates to children with milder and/or non-familial forms of dyslpidemia. Diet supplements (psyllium, oat, sterol margarine) and counselling were marginally effective in both FH/FCH children and adolescents and those without identified monogenic dyslipidemia. Exercise treatments showed minimal to no improvements in children without monogenic dyslipidemia.
9 | What are the adverse effects of drug, diet, exercise, and combination therapy in children/adolescents? | I, II-1, II-2 | Fair | Controlled and non-controlled studies of treatment reported adverse effects of drug, diet, exercise, and combination therapy in children and adolescents. Statin drugs were associated primarily with elevations in LFTs and CK. Bile-acid binding resins were associated with GI side effects and decreased levels of serum vitamins and minerals. Low fat diet has been associated with growth retardation and nurtional dwarfing in 3 children who were placed on low-fat diets without formal advice and monitoring. Most studies show normal growth and development in children over 2 years old on monitored low-fat diets. Few side effects other than elevated blood pressure were noted with exercise. The duration of follow-up in these studies ranged from 10 days to 8 years. Studies were generally not of sufficient duration to determine long-term effects of either short or extended use.
10 | Does improving dyslipidemia in childhood reduce the risk of dyslipidemia in adulthood? | None
11 | What are the cost issues involved in screening for dyslipidemia in asymptomatic children? | None

Abbreviations

CHD=Coronary heart diesease, CK=Creatine kinase, FH=Familial hyperlipidemia, FCH=Familial Combined Hyperlipidemia, HDL=High-density Lipoprotein, LDL=Low-density Lipoprotein, LFT=Liver function test, NCEP=National Cholesterol Education Program, RCT=Randomized controlled trial, TC=Total cholesterol, TG=Triglycerides

Normal values for lipids in children are currently defined according to population levels (percentiles). The NCEP has defined levels of LDL-C for which drug treatment (LDL-C >190 mg/dL or LDL-C >160 mg/dL with family history of early CHD), further evaluation, diet therapy and testing (LDL-C >130 mg/dL), and diet therapy with increased surveillance (LDL-C 110–129 mg/dL) are recommended. There is concern that the LRC values that have defined normal lipid levels in children were performed with such rigor (assured fasting, research coordinators to facilitate follow-up) that they may not be applicable to a general screening population where assessments are less controlled. Also, demographic shifts toward a more overweight population of children may make the LRC values less representative of the current population.

The most appropriate screening test is one that accurately predicts future risk and benefit from treatment. Screening recommendations for children with a family history of parental high cholesterol include an initial TC followed by a repeat TC and/or lipoprotein profile depending on the degree of elevation in TC. In practice, screening is often performed using TC and HDL-C, rather than TC alone follow-up by lipoprotein analysis if indicated by guidelines. Using LRC data, fasting TC > the 95^th^ percentile detected an LDL-C above the 95^th^ percentile for age and gender with 69% sensitivity and 98% specificity. However, recent data suggest that no single value of TC is sufficient to place a child confidently in the NCEP risk categories. Assessments of the diagnostic accuracy with which LDL-C levels predict familial hypercholesterolemia (FH) have been performed in known FH families, but not tested in the general population of children. The gold standard for diagnosis of FH is mutation analysis or fibroblast LDL-C receptor activity level testing. These confirmatory tests have not been applied to population screening trials.

Studies of lipid level tracking within childhood and from childhood to adulthood demonstrate large ranges of correlation. Serial correlations measured in individual children over time are more consistently higher for TC (r=0.38–0.78) and LDL-C (r=0.4–0.7), than for HDL-C (r=0–0.8) and TG (r=0.1–0.58). Approximately 40–55% of children with elevated lipids (by percentile) will continue to have elevated lipids on follow-up. Of those in the highest quintile of TC at follow-up, 15–19% had TC levels in the 1^st^ or 2^nd^ (lowest) quintiles at baseline.

Evidence for risk factors other than family history for predicting dyslipidemia in children is strongest for overweight, but otherwise lacking. Epidemiologic cross-sectional and cohort studies establish a strong statistical association between overweight and dyslipidemia. A BMI ≥ 95^th^ percentile, has been shown to be a stronger correlate of cumulative CHD risk (OR=19.2; 95% CI 7.6–48.5) than hyperinsulinemia. However, the magnitude of the effect of overweight on lipids, and the potential impact of incorporating overweight into a screening tool for dyslipidemia have not been addressed. Some risk factors may be useful for identifying groups of children and/or adolescents with idiopathic dyslipidemia. Multiple other risk factors (diet, physical inactivity, and aerobic capacity/fitness) have not been evaluated adequately to assess their contribution to dyslipidemia in children or their usefulness as screening tools either alone or in combination.

Currently recommended screening strategies have low adherence by providers, and limited compliance by parents and children. No trials compare strategies (location, venue, age, provider) for screening in children and adolescents. No studies address the frequency and optimal age for testing. Family history questions have limited diagnostic accuracy and have not been universally agreed upon. Studies of screening in children and adolescent and NCEP evaluate measures of TC, while adult guidelines focus on TC and HDL-C. Some experts suggest applying TC and HDL-C screening tests to children and adolescents.

There is a growing literature on the association between lipid levels in children and non-invasive vascular outcomes. Carotid intima-media thickness (IMT) is significantly higher among overweight children compared to non-overweight children, ^302^ and among children with FH compared with non-affected siblings. ^83^ Impaired nitrate dilation is lower and brachial IMT higher in children with diabetes and FH compared with healthy children. ^303^ Data from the Muscatine cohort demonstrate that measurement of adult carotid IMT correlates with lipid measurements taken in childhood, and those with TC in the upper quartile as measured at age 8–18 had an OR of 1.53 (men) and 1.43 (women) for a 1 standard deviation increase in carotid IMT. ^304^ Further exploration into arterial IMT as a risk factor identifiable in children may be warranted to evaluate its usefulness in screening and/or decisions about treatment. ^305^

Adverse effects of screening include parental non-compliance with screening and follow-up recommendations. This is reported to be related to concerns about test accuracy, lack of proof that intervention makes a difference in children, concerns about upsetting the child, refusal by the child, inconvenience, or decisions to institute a diet themselves and have the child rechecked subsequently.

Drug treatment for dyslipidemia in children has been studied only in children with FH, the population for whom these drugs are FDA-approved and recommended by the NCEP. Statins are effective for reducing TC and LDL-C in children with FH. It is not clear how this efficacy translates to children with milder and/or non-monogenic dyslipidemia (i.e. idiopathic dyslipidemia), and it is not known how frequently these medications are used in children without FH in practice. Studies of bile acid binding resins demonstrate improved TC and LDL-C, but were few and fair/poor quality. Niacin has been used, but is not FDA approved for children. ^266,^ ^306^ Target lipid levels for children who warrant treatment for dyslipidemia are outlined in the NCEP and AAP guidelines (Fig 1); the recently updated adult (ATP III) guidelines suggest more aggressive targets for adults that are not applicable to children.

Diet supplements (psyllium, oat, sterol or stanol margarines) and advice were minimally effective in both children and adolescents with FH or FCH and those without. Exercise treatments provided little to no improvement in children and adolescents without identified monogenic dyslipidemia. There were no RCTs of exercise in FH populations.

Adverse effects of treatment are reported in controlled and non-controlled studies of drug, diet, exercise, and combination therapy in children and adolescents. Statin drugs were associated primarily with elevations in LFTs and CK. Bile-acid binding resins were associated with GI side effects and decreased levels of serum vitamins and minerals. Niacin has not been systematically studied in children. Low-fat diets have been associated with growth retardation, nutritional dwarfing, and inadequate calorie and nutrient intake in children placed on a low-fat diet prior to formal nutrition counseling. ^278,^ ^285^ Other studies report normal growth and development in children over 2 years of age on monitored low-fat diets. Few side effects other than elevated blood pressure in children with FH were noted with exercise. The duration of follow-up in these studies ranged from 10 days to eight years. Studies were generally not of sufficient duration to determine long-term effects of either short or extended use.

## Limitations of the Literature

In assessing the evidence for screening and treatment of children with dyslipidemia, there remain several areas of uncertainty. Current screening guidelines are based on population norms obtained 30 years ago and do not take into account age, sex, race differences and temporal trends. They are based on family history assessments that have been shown to miss large numbers of children with dyslipidemia and that might lead to bias against detecting elevated lipids in African American children and adolescents, or children and adolescents from single-parent families. Tracking studies follow large percentiles (quartiles, quintiles) rather than focusing on those children and adolescents above the 95^th^ percentile who are likely to have the highest risk. Risk factors that might contribute to a risk assessment tool have not been adequately studied. Screening strategies including methods for assuring adequate assessment of minorities and those with unknown family history, and improving provider and parental compliance with guidelines deserve attention. Studies of statins include only children with FH, are relatively small and of short duration. There are no trials with long-term follow-up for adult lipid outcomes or CHD-related events. Studies of treatments (drug, diet and exercise) for dyslipidemia could be improved by use of more rigorous study designs, enrollment of larger population-based samples and systematic reporting of adverse effects.

In summary, although many studies about various aspects of dyslipidemia in children have been published, there are conclusive answers for few of the questions addressing primary care providers when faced with screening the general population of children and adolescents. Good evidence exists for the efficacy of statin treatments in children and adolescents with FH and the unreliable diagnostic accuracy of family history for detecting high lipid levels in children. Although current literature demonstrates imperfect tracking of TC and LDL-C through childhood and from childhood to adulthood, there are no studies evaluating tracking for those with lipids above the 95^th^ percentile. Guidelines remain based on LRC data rather than updated population norms.

## Future Research

Directions for future research should include identification of the impact that risk factors other than family history (such as overweight, physical inactivity) have on lipids, in order to develop risk assessment tools. Such tools may provide a better indication of a child's actual risk, and could serve to facilitate screening by narrowing the number of children requiring serum lipid testing. Further research into non-invasive screening strategies for screening, such as arterial IMT may be useful. ^304^ Randomized controlled clinical trials of screening strategies to determine those that may be more effective than those currently in practice, both in terms of parental compliance and provider adherence to guidelines are important. There should be continued follow-up of currently established cohorts to assess the impact of screening for dyslipidemia in childhood on adult CHD outcomes.

To further assess the efficacy and safety of treatment options in children and adolescents with dyslipidemia, long-term follow-up of children treated with statins for impact of sustained improvement of lipid in childhood on adult lipid levels, adult CHD-outcomes and long-term safety will be useful. The impact of exercise on lipid levels should be evaluated further, particularly in children with lipid levels above the 95^th^ percentile. There is a need for improved reporting of adverse effects in trials and use of standardized methods for reporting so that data can be combined across trials. Cost-effectiveness of universal screening vs. screening via family history as currently recommended should be evaluated.