# Results

## Key Question 1. Is Screening for Dyslipidemia in Children/adolescents Effective in Delaying the Onset and Reducing the Incidence of CHD-related Events?

No studies evaluated the effect of screening children and adolescents on adult lipid or disease outcomes.

## Key Question 2. What is the Accuracy of Screening for Dyslipidemia in Identifying Children/adolescents at Increased Risk of CHD-related Events and Other Outcomes?

The following sub-questions to Key Question 2 address the accuracy and feasibility of screening children for dyslipidemia.

## Key Question 2a. What are Abnormal Lipid Values in Children/adolescents?

### Summary

Normal lipid values for children are defined according to percentile cut points within population distributions. In large population-based samples, TC levels increase from birth, stabilize at approximately age two years, peak prior to puberty, then decline slightly. NCEP recommendations are based on results from the Lipid Research Clinics (LRC) Prevalence Study, which determined the 95th percentile cut point for TC as 200 mg/dL and for LDL-C as 130 mg/dL. More recent studies indicate age, sex, and racial differences and temporal trends that shift these cut points.

### Evidence

Although several studies conducted in the U.S. during the 1970s obtained lipid levels from large samples of normal healthy children, ^51^ – ^53^ current recommendations ^11,^ ^34,^ ^35,^ ^54^ are based on distributions of lipid and lipoprotein levels obtained from the Lipid Research Clinics (LRC) Prevalence Study. ^14^ This study included one Canadian and nine U.S. sites and enrolled subjects primarily based on residency within census tracts, school enrollment, and employment in occupational and industrial groups. Fasting (≥12 hours) lipid and lipoprotein levels were obtained in 15,626 children age 0–19 years between 1972-1976. The selected populations included a broad range of geographic, socio-economic, occupational, sex, and ethnic groups, but they were not selected to be a representative sample of the North American population.

In the LRC sample, TC levels increased from birth and stabilized at approximately age two years. At puberty, TC levels declined slightly for both boys and girls, and HDL-C levels declined for boys. For all children, the mean serum level for TC was approximately 160 mg/dL and for LDL-C was 100 mg/dL. The 95^th^ percentile level was 200 mg/dL for TC and 130 mg/dL for LDL-C (Table 2). Results for African American children were similar, however, they were based on smaller numbers and provided TC and triglycerides only. ^14^

Table 2 Lipid Research Clinics Lipid Levels Iin U.S. Children and Adolescents

| | | Percentiles
Age (years) | N | Mean | 5 | 10 | 25 | 50 | 75 | 90 | 95
Total Cholesterol (mg/dL)*^,†^
Males
0–4 | 238 | 159 | 117 | 129 | 141 | 156 | 176 | 192 | 209
5–9 | 1253 | 165 | 125 | 134 | 147 | 164 | 180 | 197 | 209
10–14 | 2278 | 162 | 123 | 131 | 144 | 160 | 178 | 196 | 208
15–19 | 1980 | 154 | 116 | 124 | 136 | 150 | 170 | 188 | 203
Females
0–4 | 186 | 161 | 115 | 124 | 143 | 161 | 177 | 195 | 206
5–9 | 1118 | 169 | 130 | 138 | 150 | 168 | 184 | 201 | 211
10–14 | 2087 | 164 | 128 | 135 | 148 | 163 | 179 | 196 | 207
15–19 | 2079 | 162 | 124 | 131 | 144 | 160 | 177 | 197 | 209
Low-Density Lipoprotein (LDL) Cholesterol (mg/dL)*^,†^
White Males
5–9 | 131 | 95 | 65 | 71 | 82 | 93 | 106 | 121 | 133
10–14 | 284 | 99 | 66 | 74 | 83 | 97 | 112 | 126 | 136
15–19 | 298 | 97 | 64 | 70 | 82 | 96 | 112 | 127 | 134
White Females
5–9 | 114 | 103 | 70 | 75 | 91 | 101 | 118 | 129 | 144
10–14 | 244 | 100 | 70 | 75 | 83 | 97 | 113 | 130 | 140
15–19 | 294 | 99 | 61 | 67 | 80 | 96 | 114 | 133 | 141
High-Density Lipoprotein (HDL) Cholesterol (mg/dL)*^,†^
White Males
5–9 | 142 | 57 | 39 | 43 | 50 | 56 | 65 | 72 | 76
10–14 | 296 | 57 | 38 | 41 | 47 | 57 | 63 | 73 | 76
15–19 | 299 | 48 | 31 | 35 | 40 | 47 | 54 | 61 | 65
White Females
5–9 | 124 | 55 | 37 | 39 | 48 | 54 | 63 | 69 | 75
10–14 | 247 | 54 | 38 | 41 | 46 | 54 | 60 | 66 | 72
15–19 | 295 | 54 | 36 | 39 | 44 | 53 | 63 | 70 | 76
Triglycerides (mg/dL)*^,†^
Males
0–4 | 238 | 58 | 30 | 34 | 41 | 53 | 69 | 87 | 102
5–9 | 1253 | 30 | 31 | 34 | 41 | 53 | 67 | 88 | 104
10–14 | 2278 | 68 | 33 | 38 | 46 | 61 | 80 | 105 | 129
15–19 | 1980 | 80 | 38 | 44 | 56 | 71 | 94 | 124 | 152
Females
0–4 | 186 | 66 | 35 | 39 | 46 | 61 | 79 | 99 | 115
5–9 | 118 | 30 | 33 | 37 | 45 | 57 | 73 | 93 | 108
10–14 | 2087 | 78 | 38 | 45 | 56 | 72 | 93 | 117 | 135
15–19 | 2079 | 78 | 40 | 45 | 55 | 70 | 90 | 117 | 136

Key

* Adapted from National Heart, Lung, and Blood Institute 1980 ^14^

† All values have been converted from plasma to serum. Plasma value X 1.03 = serum value.

To determine racial differences, a study of a multi-racial sample of 6,585 U.S. children ages 5–18 years from 22 schools in five states reported non-fasting finger-stick plasma TC levels from 1984-88. ^55^ The mean TC level for African American children (173 mg/dL) was significantly higher (p<0.001) than for Hispanics (168 mg/dL), Asians (165 mg/dL), and Whites (163 mg/dL) (Table 3). The mean TC level for Hispanics was significantly higher than for Whites (p<0.001) but not Asians, and higher for girls than boys for Whites only (165 mg/dL vs. 160 mg/dL, p<0.001).

Table 3 Total Cholesterol Levels by Race*

| | | Percentiles
Race/Ethnicity | N | Mean mg/dL + SEM^†^ | 50th | 75th | 90th | 95th
White | 2724 | 162.6 ± 0.537 | 161 | 180 | 198 | 209
Black | 1383 | 172.9 ± 0.830 | 171 | 192 | 210 | 225
Asian | 177 | 165.4 ± 2.120 | 165 | 181 | 204 | 219
Hispanic | 1453 | 167.9 ± 0.734 | 166 | 184 | 203 | 216
Total ^‡^ | 5871 | 166.4 ± 0.357 | 165 | 184 | 202 | 215

Key

* Adapted from Resnicow, 1989 ^55^

† 95% confidence interval = ± 1.96 (standard error of the mean).

‡ Includes unclassified children

More recent data from the National Health and Nutrition Examination Survey (NHANES) III (1988-94) confirm many of these findings. However, in NHANES III mean TC levels among 12–17 year olds decreased by 7 mg/dL from the National Health Examination Survey (NHES) III (1966-1970) and NHANES I (1971-1974) levels shifting percentile cut points upward. ^56^ NHANES III data from 7,499 children and adolescents ages 4–19 years indicate a 95^th^ percentile cut point for serum TC as 216 mg/dL and for LDL-C as 152 mg/dL. ^56^ Mean age-specific TC levels peaked at 171 mg/dL at 9–11 years and declined at older ages. Girls had significantly higher mean TC and LDL-C levels than boys (p<0.005). Non-Hispanic Black children and adolescents had significantly higher mean TC, LDL-C, and HDL-C levels compared to non-Hispanic White and Mexican American children and adolescents. In linear regression models of these data, age, sex, and race have significant effects on lipid levels questioning the utility of fixed screening cut points. ^57^

## Key Question 2b. What are the Appropriate Tests? How Well do Screening Tests (Non-fasting Total Cholesterol, Fasting Total Cholesterol, Fasting Lipoprotein Analysis) Identify Individuals with Dyslipidemia?

An appropriate screening test is one that has a strong association with future risk for CHD, or one that can be used to identify people who benefit from treatment.

### Summary

TC minus HDL-C above the 95^th^ percentile is 88–96% sensitive and 98% specific for detecting LDL-C ≥130 mg/dL. However, a single TC or HDL-C measurement is insufficient for practitioners to assign children and adolescents to the NCEP risk categories with 95% confidence.

Identification of familial hypercholesterolemia (FH) has traditionally used LDL-C levels alone or combined with family history. In families with known FH, LDL-C levels above the 95^th^ percentile detect FH among first-degree relatives with 95% sensitivity. However, the ability of LDL-C to predict FH decreases when using second and third degree relatives of an FH proband, and decreases further when applying these criteria to the general population. Lipid Research Clinics (LRC) data indicate that TC > the 95^th^ percentile is 69% sensitive and 98% specific for detecting children and adolescents (ages 6–19) with LDL-C > the 95^th^ percentile and TG < the 95^th^ percentile for age and gender. No studies have evaluated lipid levels in the general U.S. population as a diagnostic test for FH using mutation or biochemical analysis as the gold standard.

### Evidence

In AAP and NCEP guidelines, TC is used as an initial laboratory measurement for children being tested because of a family history of high cholesterol, and a lipoprotein profile is obtained if the patient has a TC over a certain defined target. In children, as in adults, LDL-C is the basis for initiating treatment and determining goals of therapy. How well TC levels detect elevated LDL-C levels has been examined in three different populations, using LRC data (ages 6–19, n=1325), ^58^ Hispanic children (ages 4–5, n=106) ^59^ and the biracial Bogalusa cohort (ages 5–17, n=2,857). ^60^ TC> the 95^th^ percentile detected LDL > the 95^th^ percentile with sensitivities of 44% (White females) to 50% (White males, African American males and females). ^60^ Specificities were 90% (African American and White males and females). ^60^ With LRC data, a fasting TC > the 95^th^ percentile had 69% sensitivity and 98% specificity for detecting children with LDL > the 95^th^ percentile and TG <the 95th percentile. ^58^ Using a lower threshold of fasting TC ≥ 75^th^ percentile to detect LDL ≥ the 95^th^ percentile in a sample of Hispanic children ages 4–5, sensitivities were 86% (using an LRC defined 75^th^ percentile) and 96% (using the sample defined 75^th^ percentile), and specificities were 93% (LRC defined) and 87% (sample defined). ^59^ Variations in test characteristics are likely due to population differences, or slight differences in definitions of the percentile definition. Use of an absolute cut-off rather than an age and gender adjusted percentile results in higher sensitivity and lower specificity for females. ^58^

In adults, the recommended screening tests are TC and HDL-C. While this has not been recommended in guidelines for children and adolescents, it is common in practice. ^61^ HDL-C may help distinguish false negatives from true negatives among those screened with TC alone. ^58^ The use of TC and HDL-C in combination as a screening tool has been evaluated ^62,^ ^63^ In 260 African American adolescents (ages 12–20), fasting TC minus HDL-C above the 95^th^ percentile was 96% sensitive and 98% specific for predicting LDL-C ≥130 mg/dL. Using data from adolescents who were both non-fasting and fasting, TC minus HDL-C was 88% sensitive and 98% specific. ^62^

Using weekly repeated measures of TC and HDL-C, within-person variability and the ability of these tests to reliably classify children and adolescents into NCEP risk categories (TC<170 mg/dL acceptable, TC 170–199 mg/dL borderline, and ≥200 mg/dL high; and for HDL-C <35 mg/dL low, and ≥35 mg/dL acceptable) were assessed. A child needed to have a TC level below 155 mg/dL or above 185 mg/dL to be assigned a category of acceptable or borderline/high (respectively) based on a single measurement. To accurately assign a child to the high category with 95% confidence, a TC > 215 mg/dL was required. No single TC value would place a child in the borderline category (170–200 mg/dL) with 95% confidence. Averaging two TC readings improved the ability to classify children with 95% confidence: a TC <159 mg/dL could reliably assign a child to the acceptable category and a TC of >211 mg/dL could reliably assign a child to the high category. Three TC measurements did not substantially improve the ability to classify children into risk categories. ^63^

Likewise, one measurement of HDL-C was required to be <28 mg/dL or > 43 mg/dL to confidently assign (based on the 95% confidence interval) the child to a low HDL (<35 mg/dL) or acceptable (>35 mg/dL) category. With two HDL measurements, the values required were <30 mg/dL and >40 mg/dL respectively. ^63^

Direct LDL-C measurement offers the advantage of using nonfasting serum samples. It may be as precise as that calculated LDL-C using the Friedewald formula, ^64^ but this remains controversial. Immunoseparation and direct determination of plasma LDL-C correctly classified 81% of children according to NCEP cut-offs, compared to 84% of children correctly classified using the Friedewald formula. ^64^ In another study, however, direct LDL-C correctly classified 83% and 81% of those children with LDL-C >130 mg/dL and ≥190 mg/dL respectively, but only 43–55% of those with LDL-C 130–190 mg/dL. This compared with the Friedwald formula which correctly classified 79–82% of the group between 130–190 (using a gold standard that was β-quantification LDL). ^65^

A primary goal of screening in children and adolescents is to identify individuals who are at risk for premature CHD and would benefit from early treatment. The most prevalent condition leading to early CHD is familial hypercholesterolemia (FH). Clinical definitions of FH vary (Table 4A ^34^ – ^36^ and 4B ^38,^ ^39,^ ^66^ – ^83^ ). Many studies assume FH is present based on LDL-C levels and clinical data. Studies have used LDL-C levels above the 95^th^ percentile for age and gender with a family history of early CHD as a diagnostic criterion for FH. Others have used LDL-C above a certain level (LDL-C cutoff varies among studies) and a parent with FH, but it is often unclear how the parental diagnosis was made. Still others have used LDL-C levels along with the presence of xanthomas to define FH, though xanthomas are rare in children with FH, especially young children.

Table 4a Guideline Definitions of High Risk

| AAP* 1998 | AHA^†^ 2003 | NCEP^‡^ 1992
Guidelines for High Risk
LDL ≥ 190 after 1 year low fat and low cholesterol diet | | | X
LDL > 160 with familial premature heart disease (before 55 years of age) | | | X
LDL > 160 with ≥ 2 other CVD risk factors in child or adolescent (such as low HDL cholesterol [<35 mg/dL], cigarette smoking, high blood pressure, obesity, or diabetes, etc.) | | | X
LDL > 110 mg/dL, or TC > 170 mg/dL (borderline risk), TC > 200 mg/dL, or LDL > 130 mg/dL, or TG > 150 mg/dL, or HDL < 35 mg/dL (elevated risk) | | X
Screen if: | X
Parents or grandparents with premature (≤ 55 years old) coronary atherosclerosis or documented MI, angina, peripheral vascular disease, cerebrovascular disease, or sudden cardiac death, or parent with total cholesterol ≥ 240 mg/dL
Risk if above is true and:
LDL 110–129 mg/dL, or TC 170–199 mg/dL (borderline risk)
LDL ≥ 130 mg/dL, or TC ≥ 200 mg/dL (high risk)

Key

* American Academy of Pediatrics, 1998 ^35^

† American Heart Association ^36^

‡ National Cholesterol Education Program, 1992 ^34^

Abbreviations

CVD=Cardiovascular disease, HDL=High-density lipoprotein, LDL=Low-density lipoprotein, MI=Myocardial infarction, TC=Total cholesterol, TG=Triglycerides

Table 4b Inclusion Criteria for Studies of Children with Familial Hypercholesterolemia

| Treatment trials
| Clauss 2005 ^38^ | Couture 1998 ^66^ | Davidson 1996 ^67^ | de Jongh 2002a ^68^ | de Jongh 2002b ^69^ | de Jongh 2003 ^70^ | Gylling 1995 ^38^ | Knipscheer 1996 ^71^ | Lambert 1996 ^72^ | Malloy 1978 ^73^ | McCrindle 1997 ^74^ | McCrindle 2002 ^75^ | McCrindle 2003 ^76^ | Stallings 1993 ^77^ | Stein 1999 ^78^ | Sveger 2000 ^79^ | Tonstad 1996a ^80^ | Tonstad 1996b ^81^ | Wheeler 1985 ^82^ | Wiegman 2004 ^83^
Inclusion Criteria
LDL values with or without other risk factors
LDL 189 – 503 mg/dL and at least 1 parent with LDL ≥ 189 mg/dL not due to secondary causes | | | | | | | | | | | | | | | X
LDL 220 – 503 mg/dL and a parent death from CAD with no available lipid values | | | | | | | | | | | | | | | X
LDL ≥ 190 mg/dL with TG ≤ 400 mg/dL | | | | | | | | | | | | | X
LDL > 190 mg/dL and parent with hypercholesterolemia (TC >290 mg/dL) or early CHD death | | | | | | | | | | | | | | | | X
LDL 158.5 – 398.3 mg/dL | | | | | X
Two fasting LDL levels ≥ 155mg/dL and triglycerides < 350 mg/dL, and 1 parent with definite FH (clinical or molecular diagnosis) | | | | | | | | | | | | | | | | | | | | X
LDL 160 – 400 mg/dL, and parental history of heterozygous familial hypercholesterolemia | X
Fasting LDL cholesterol level before enrollment > 160 mg/dL and family history of hypercholesterolemia or premature CHD in first degree relatives, and minimum | | | | | | | | | | | | X | X
Fasting serum LDL of ≥ 130 mg/dL while on American Heart Association step 2 diet | | | | | | | | | | | X
LDL > 95th percentile for age/gender | | | | X | | X
LDL > 95th percentile for age/gender or age while on lipid lowering diet | | X | | | | | | | X | | X
LDL > 95th percentile for age/gender or age while on lipid lowering diet, with documented family history of hyperlipidemia or hypercholesterolemia in siblings/parents/grandparents | | | | X | | | | X | X
LDL > 95th percentile for age while on lipid lowering diet, with documented family history of premature CHD < age 50 in first or second degree relatives | | | | | | | | X | X
LDL > 95th percentile for age, while on lipid lowering diet, and history f unsuccessul treatment with BABR. | | | | | | | | | X
LDL > 90th percentile for age/gender, with triglycerides ≤ 300 mg/dL | | | X
Plasma LDL between 90th – 99th percentile | | | | | | | | | | | | | | X
TC ≥ 300 mg/dL while on ≥ 4 months of lipid lowering diet | | | | | | | | | | X
Genetic mutations
Diagnosis of FH established in children and in 1 parent mostly by DNA technique | | | | | | | X
Personal diagnosis by detection of mutation at the LDL receptor gene | | X | | X | | X | | | X | | | | | | | | X
Other inclusion criteria including combinations
TC ≥ 301.6 mg/mL and tendon xanthoma in one or both parents and in relatives in a manner compatible with autosomal dominant inheritance | | | | | | | | | | | | | | | | | X
TC > 290 mg/dL and first degree relative with MI <age 50 (males) or <age 55 (females) | | | | | | | | | | | | | | | | X
TC > 260 mg/dL and triglyceride levels < 200 dL, and 1 parent had baseline cholesterol > 300 mg/dL, and triglyceride levels < 200 or tendon xanthoma, and autosomal dominant inheritance present in other members | | | | | | | | | | | | | | | | | | X
TC > 259 mg/dL, a type IIa pattern on lipoprotein electrophoresis, and fasting triglyceride < 58.0 mg/dL in the patient, with either similar lipoprotein abnormalities in one of the parents, or premature CHD death in a parent and a similar lipid abnormality in another close relative | | | | | | | | | | | | | | | | | | | X

Abbreviations

BABR=Bile acid binding resin, CAD=Coronary artery disease, CHD=Coronary heart diease, CVD=Cardiovascular disease, FCH=Familial combined hyperlipidemia, FH or heFH=Familial hyperlipidemia, LDL=Low density lipoprotein, MI=Myocardial infarction, TC=Total cholesterol, TG=Triglycerides

The gold standards for diagnosis of FH include either molecular genetic studies identifying a pathogenic mutation in the LDL-C receptor gene, or biochemical studies showing defective LDL-C receptor activity in cultured fibroblasts. Over 800 LDL-C receptor mutations have been identified in FH, ^30,^ ^84,^ ^85^ thereby complicating diagnostic confirmation. Some populations (South African Afrikaners, Finnish, French Canadian) have limited numbers of mutations, ^30,^ ^85^ but this is not true of the U.S. population. LDL-C receptor activity assays are expensive, difficult and not widely available. ^30^ As a result, clinical trials reporting results in children with FH for the most part included children who likely have FH but who have not had diagnostic confirmation (Table 4B).

Although genetic screening has been evaluated in populations where there are few known mutations causing FH, ^86,^ ^87^ no studies have evaluated LDL-C levels in a general population of U.S. children identified through lipid screening and confirmed suspected cases of FH with mutation analysis. Several descriptive epidemiologic studies have used LDL-C levels for diagnosis within identified FH families ^88^ – ^90^ Even among these studies, only one used families identified by mutation analysis, ^89^ whereas the others used families identified by either mutation analysis or LDL-C above the 95^th^ percentile along with tendon xanthomata, ^88^ or by lipid levels alone. ^29^ LDL-C levels greater than 135 mg/dL, ^88^ and LDL-C levels above the 95^th^ percentile for age and gender among 1^st^ degree relatives of an FH proband ^89^ captured 95% of FH cases within families.

The difference in the predictive value of LDL-C levels for diagnosing individuals within families as opposed to in the general population was nicely demonstrated by a study of relatives from 5 large, LDL-C receptor mutation confirmed Utah FH pedigrees. Data from this cohort were used to assess the sensitivity and specificity of mathematically-derived screening criteria in the population of relatives. ^91^ Differences in predictive values for total cholesterol among 1^st^, 2^nd^, and 3^rd^ degree relatives of persons with FH were evaluated and demonstrated graphically (Figure 4). The predictive value of a specific LDL-C level to diagnose FH decreases substantially for 1^st^, 2^nd^, and then 3^rd^ degree relatives of FH, and is even lower for the general population. Thus, TC and LDL-C levels that were evaluated for diagnosing FH using FH kindreds do not allow for application of identified LDL-C levels to non-FH families or to general populations. There were no studies identified that evaluated LDL-C levels in a general population of children or adolescents that subsequently confirmed suspected (screen identified) cases of FH with mutation or biochemical analysis.

Figure 4. Probability Distribution for Heterozygous Familial Hypercholesterolemia, Relative, and the General Population

## Key Question 2c. How Well do Lipid Levels Track from Childhood to Adulthood?

### Summary

Serial correlations between lipid levels measured in individual children over time are higher for TC (r=0.38–0.78) and LDL-C (r=0.4–0.7), than for HDL-C (r=0–0.8) and TG (r=0.1–0.58). Tracking is generally consistent within a cohort. Age at first measurement and duration of follow-up do not appear to be related to strength of the correlation between measurements. Approximately 40–55% of children with elevated lipids defined by percentile within a population distribution will continue to have elevated lipids on follow-up. Likewise, the highest quintile of TC at follow-up consists of children and adolescents from the 1^st^ (4–6%), the 2^nd^ (11–13%), the 3^rd^ (19–20%) and the 4^th^ (18–21%) quintiles at baseline. There were no studies of tracking according to other risk factors.

### Evidence

Twenty-three prospective cohort studies contributed information on tracking of lipid levels during childhood. Twenty-one studies reported correlation coefficients and are listed on Evidence Table 1, ^3,^ ^17,^ ^92^ – ^110^ whereas 2 studies reported tracking only by percentile and are described in the text. ^111,^ ^112^ These studies drew from seven U.S. cohorts and eight non-U.S. cohorts.

Correlation coefficients from these studies are displayed both by age at first measurement (Figures 5A–5D) and duration of follow-up (Figures 6A–6D). In both displays, TC and LDL-C track more consistently than do HDL-C and TG. There does not appear to be a clear pattern of improvement in tracking of cholesterol levels with either increasing age or shorter duration of follow-up. Studies noted better tracking for boys and African Americans. ^3,^ ^17,^ ^108^ The range of correlation coefficients (or tracking coefficients) among the U.S. cohort studies is 0.38 to 0.78 for TC, 0.4 to 0.71 for LDL-C, 0 to 0.79 for HDL-C and 0.1 to 0.58 for TG. HDL-C tracking was worse in one study from the Muscatine cohort (0 to 0.1) than in studies from other cohorts (0.2 to 0.79).

Figure 5a. Studies of Tracking: Total Cholesterol Levels Based on Age at Start of Study

Figure 5b. Studies of Tracking: LDL-C Levels Based on Age at Start of Study

Figure 5c. Studies of Tracking: HDL-C Levels Based on Age at Start of Study

Figure 5d. Studies of Tracking: Triglyceride Levels Based on Age at Start of Study

Figure 6a. Studies of Tracking: Total Cholesterol Levels Based on Duration of Study

Figure 6b. Studies of Tracking: LDL-C Levels Based on Duration of Study

Figure 6c. Studies of Tracking: HDL-C Levels Based on Duration of Study

Figure 6d. Studies of Tracking: Triglyceride Levels Based on Duration of Study

Studies also reported the percentage of children remaining in high-cholesterol classification categories at follow-up (Table 5A). ^3,^ ^92,^ ^94,^ ^95,^ ^98,^ ^99,^ ^105,^ ^111^ Of children ages 5–18 with two consecutive cholesterol measurements above the 90^th^ percentile in the Muscatine cohort who had lipids measured again at ages 20–30 (n=70), 34% had adult cholesterol levels ≥ 240 mg/dL, 37% had adult levels between 200–239 mg/dL, and 29% had adult levels < 200 mg/dL. ^113^ In the Bogalusa cohort, 196 children were classified in the highest quintile of TC at year one; of those, 55% remained in the highest quintile eight years later. ^17^ The Child and Adolescent Trial for Cardiovascular Health (CATCH) cohort study is large (n=3,659) and more recent, but has not yet followed the cohort through to adulthood. ^3^ Between 3^rd^ and 8^th^ grades, 53% remained in the lower quintile and 55% in the highest quintile of TC. Fifty-three percent remained in the lowest quintile and 55% in the highest quintile for HDL-C. ^3^

Table 5a Cholesterol Tracking by Risk Group at Baseline

Study, n, and Cohort Came | Age at End of Study (years) | Length of Follow-Up (years) | Risk Group at Baseline | Results at Follow-Up for Risk Group
Kallio, 1993 ^105^ | 5 | 4 | TC in top quartile | 40% remained in top quartile
n=162
Helsinki, Finland
Kelder, 2002 ^3^ | 13 (8th grade) | 4 | TC in top quintile | 55% remained in top (5th quintile); 80% remained in either 4th or 5th quintile
n=3,659 | | | HDL in top quintile | 55% remained in top (5th) quintile; 79% remianed in either the 4th or 5th quintile
Child and Adolescent Trial for Cardiovascular Health (CATCH)
Laskarzewski, 1979 ^98^ | 11–18 | 4 | TC in top decile (13 of 108) | 6 of 13 remained in top decile
n=108 | 11–18 | 3 | LDL in top decile (at 1 yr; 11 of 108) | 3 of 11 remained in top decile
Cincinnati LRC Princeton School
Clarke, 1978 ^94^ | 11–25 | 6 | TC in lowest quintile | 12% were above the 3rd quintile
n=820 | 11–25 | 6 | TG in middle quintile | Equally distributed (20% in each quintile)
Muscatine
Guo, 1993 ^99^ | 19–21 | 10–12 | LDL>2.84 mmol/L | 10% probability of LDL>3.62 mmol/L
n=96 | 19–21 | 10–12 | LDL>3.1 mmol/L | 17% probability of LDL >3.62 mmol/L
Fels Longitudinal Study | 19–21 | 10–12 | LDL>3.36 mmol/L (130mg/dL) | 26% probability of LDL>3.36 mmol/L
| 19–21 | 10–12 | TC>4.8 mmol/L | 5% probability of TC>5.69 mmol/L
| 19–21 | 10–12 | TC>5.2 mmol/L (200 mg/dL) | 19% probability of TC> 5.69 mmol/L
Nicklas, 2002 ^111^ and Bao, 1996 ^92^ | 20–29 | 15 | TC or LDL in top quintile | >40% remained in top quintile
n=1,169
Bogalusa Heart Study
Lauer, 1989 ^95^ | 20–30 | 10–14 | TC>90th percentile at baseline | 24–32% had adult TC>90th percentile
n=2,446 | 20–30 | 10–14 | Any TC measurement >90th percentile during the course of study | 42% had adult TC>90th percentile
Muscatine

Abbreviations

HDL=High-density lipoprotein, LDL=Low-density lipoprotein, TC=Total cholesterol, TG=Triglycerides

Likewise, some studies have evaluated the derivation of the highest risk group at follow-up (Table 5B). ^96,^ ^105,^ ^108,^ ^112^ In the Beaver County Lipid Study individuals who were in the top quintile for TC at follow-up (ages 17–30 years), had the following distribution of TC values at baseline (ages 1–14 years): 6% had TC in the 1^st^ (lowest) quintile, 13% in the 2^nd^, 19% in the 3^rd^, 21% in the 4^th^, and 40% in the 5^th^ (highest). ^96^

Table 5b Cholesterol Tracking by Risk Group at Follow-up

Study | Age at End of Study (years) | Length of Follow-Up (years) | Risk Group at Follow-Up | Derivation of the Risk Group
Kallio, 1993 ^105^ | 5 | 4 | TC>90th percentile | 45% had TC>90th percentile at age 12 months,
n=162 | | | | 80% had TC>75th percentile
Helsinki, Finland
Porkka, 1994 ^108^ | 15–30 | 12 | Highest quintile of TC | Approximately 3% from 1st quintile, 11% from 2nd, 12% from 3rd and 28% from 4th, 45% from 5th (highest)
n=883
Cardiovascular Risk in Young Finns Study
Orchard, 1983 ^112^ | 20–24 | 9–10 | Adult TC >80th percentile | 50% were in top quintile at baseline
n= 561 | 20–24 | 9–10 | All adults with TC in top quintile | 4% from 1st quintile, 11% from 2nd, 20% from 3rd, 18% from 4th, 48% from 5th (highest)
Beaver County Lipid Study
Stuhldreher, 1991 ^96^ | 17–30 | 16 | Top quintile of TC | 6% from 1st (lowest) quintile, 13% from 2nd, 19% from 3rd, 21% from 4th, and 40% from 5th (highest)
n=295
Beaver County Lipid Study

Abbreviations

TC=Total cholesterol

Most tracking studies compared single lipid measurements over time. Repeated lipid measurements in children show variation (see above, Key Question 2a). Therefore, regression to the mean should be considered as one explanation for variability among tracked values. ^108,^ ^114^ Some adjusted for covariates, or used tracking coefficients. ^101^ None of these studies evaluated the proportion of children and adolescents with lipid levels above the 95^th^ percentile who remained in the top 5% at follow-up.

## Key Question 2d. What is the Accuracy of Family History in Determining Risk?

### Summary

Family histories can be time consuming and difficult to elicit accurately. Screening using family history has been shown to miss substantial numbers (30–60% in general) of children with elevated lipids. Family history definitions vary substantially among studies as do lipid detection thresholds. Those studies that show higher sensitivities (~77%) have low specificities (55% or lower). Population-based estimates of the number of children requiring serum lipid testing based on family history may range from 25–55%, depending on the exact definition of family history and the lipid detection threshold.

### Evidence

The AAP and NCEP advocate selective screening for dyslipidemia among children and adolescents who have a family history of early CHD or high cholesterol. Many good quality studies of diagnostic accuracy have evaluated the sensitivity and specificity of family history according to various guidelines for detecting abnormal lipids in children and adolescents (Table 6). ^59,^ ^62,^ ^115^ – ^128^ All of these studies used an appropriately broad spectrum of patients either from pediatricians' offices, schools, or ongoing cohort studies and applied tests of family history and lipid measurement equally. The studies used different definitions of the screening tool (any parental history of heart attack, other parental risk factors, varied age definitions of early CHD), and selected different levels of LDL-C or TC as the lipid detection threshold.

Table 6 Summary of Studies Evaluating Sensitivity and Specificity of Family History

Study, year | Population | Method | Threshold* | Sensitivity | Specificity | Number Eligible for Screening (based on population of 1,000)^†^ | Number Missed (based on population of 1,000)^†^
Bell, 1990 ^115^ | 1,140 5th graders | Family history of high cholesterol or MI <age 60 in parent or grandparent | non-fasting TC > 200 mg/dL | 64% | 47% | 540 | 46
| 1,140 5th graders | Above, plus family history of stroke, angina or hypertension | non-fasting TC > 200 mg/dL | 77% | 24% | 760 | 31
Davidson, 1991 ^116^ | 1,118 4th graders | Family history from parents (regarding parents, siblings, grandparents, aunts, uncles); early MI defined as < age 56 for men and women (UCI criteria) | TC > 200 mg/dL | 41% | 68% | 330 | 83
| 1,118 4th graders | Parental questionnaire, definition using AAP criteria for early CHD (< age 50 for men, < age 60 for women) | TC > 200 mg/dL | 31% | 66% | 330 | 96
Dennison, 1989 ^126^ | 1,214, ages 4–10, Bogalusa Heart Study | Parental questionnaire asking parental history of any vascular disease (CHD, HTN, diabetes, stroke) | fasting TC ≥ 95th percentile | 38% for Whites; 27% for AA-Blacks | 73% for Whites; 65% for AA-Blacks | n/a | n/a
| 2,099, ages 11–17, Bogalusa Heart Study | Parental questionnaire asking parental history of any vascular disease (CHD, HTN, diabetes, stroke) | fasting TC ≥ 95th percentile | 59% for Whites; 25% for AA-Blacks | 67% for Whites; 56% for AA-Blacks | n/a | n/a
| 1,214,ages 4–10, Bogalusa Heart Study | Parental questionnaire asking parental history of any vascular disease (CHD, HTN, diabetes, stroke) | fasting LDL ≥ 95th percentile | 41% for Whites; 20% for AA-Blacks | 73% for Whites; 63% for AA-Blacks | n/a | n/a
| 2,099, ages 11–17, Bogalusa Heart Study | Parental questionnaire asking parental history of any vascular disease (CHD, HTN, diabetes, stroke) | fasting LDL > 95th percentile | 37% for Whites; 22% for AA-Blacks | 67% for Whites; 56% for AA-Blacks | n/a | n/a
Diller, 1995 ^117^ | 232, ages 2–19, Cincinnati MI Hormone Study | Parental questionnaire using NCEP definition of family history of premature CVD | LDL ≥ 130 mg/dL | 17% | 75% | 246 | 207
| 232, ages 2–19, Cincinnati MI Hormone Study | Parental questionnaire asking family history of cholesterol > 240 | LDL ≥ 130 mg/dL | 61% | 74% | 293 | 99
| 232, ages 2–19, Cincinnati MI Hormone Study | Both family history of elevated cholesterol and premature CVD | LDL ≥ 130 mg/dL | 74% | 55% | 478 | 65
| 232, ages 2–19, Cincinnati MI Hormone Study | Other indicators: obesity, smoking, use of lipid raising medications, high fat diet, HTN | LDL ≥ 130 mg/dL | 17.4% for obesity, 9–48% for others | 86% for oebsity, 69–95% for others | 547 | 86
| 232, ages 2–19, Cincinnati MI Hormone Study | Family history of premature CHD (NCEP definition), TC>240 mg/dL, or any other risk factor (obesity, smoking, lipid raising medication, high fat diet or HTN). | LDL ≥ 130 mg/dL | 96% | 28% | 746 | 13
Gagliano, 1993 ^118^ | 224, ages 11–20 | Family history of early MI (<age 50 for men, < age 60 for women) or elevated lipids (TC >200 mg/dL), history obtained from adolescent | TC > 85th percentile for gender | 36% | 69% | 320 | 94
| 224, ages 11–20 | Family history as above, history obtained from parent | TC above the 85th percentile for gender | 65% | 46% | 589 | 54
| 224, ages 11–20 | Use of combined family history from adolescent and parent | TC above the 85th percentile for gender | 45% | 69% | 361 | 80
Griffin, 1989 ^119^ | 1,005, ages 2–13, 8 office practices | Parent and grandparent history of hypercholesterolemia or CHD < age 55 | fasting LDL > 95th percentile | 46% | NR | n/a | 147
| 1,005, ages 2–13, 8 office practices | Parent and grandparent history of any risk factor or complication (hypercholesterolemia, diabetes, HTN, gout, obesity and atherosclerosis prior to age 55) | fasting LDL > 95th percentile | 78% | NR | n/a | 59
| 1,005, ages 2–13, 8 office practices | Parent and grandparent history of hypercholesterolemia or CHD < age 55 | fasting LDL > 90th percentile | 51% | 63% | 385 | 48
| 1,005, ages 2–13, 8 office practices | Any history of parent or grandparent with a risk factor or complication (hypercholesterolemia, diabetes, HTN, gout, obesity and atherosclerosis prior to age 55) | fasting LDL > 90th percentile | 80% | 37% | 650 | 20
| | | | 38% for high cholesterol alone 31% for obesity 18% for sudden death 17% for gout 13% for PVD
| 1,005, ages 2–13, 8 office practices | Overweight (weight for height > 95th percentile) plus family history of early CHD or hypercholesterolermia | fasting LDL > 90th percentile | 57% | NR | n/a | 42
| 1,005, ages 2–13, 8 office practices | Overweight (weight for height > 95th percentile) plus family history any risk factor or complication | fasting LDL > 90th percentile | 84% | 31.0% | 704 | 16
Muhonen, 1994 ^120^ | 599, ages 14–20, Muscatine, IA | Parental history of high cholesterol | Highest decile of fasting TC | 34% | 76% | n/a | n/a
| 599, ages 14–20, Muscatine, IA | Parental history of high cholesterol | Highest decile of fasting LDL | 34% | 76% | n/a | n/a
| 599, ages 14–20, Muscatine, IA | Parental history of high cholesterol | Lowest decile of fasting HDL | 26% | 75% | n/a | n/a
O'Loughlin, 2004 ^127^ | 2,217, ages 9, 13, and 16, Quebec | Parental questionnaire asking personal history of 1) high cholesterol 2) meds for cholesterol 3) heart attack, angina, 4) stroke, CVD or PVD or 5) meds for the heart; unknown family history coded as negative | fasting LDL≥109 mg/dL (“borderline”) | 33% | 76% | 256 | 44
| 2,217, ages 9, 13, and 16, Quebec | Parental questionnaire asking personal history of 1) high cholesterol 2) meds for cholesterol 3) heart attack, angina, 4) stroke, CVD or PVD or 5) meds for the heart; unknown family history coded as negative | fasting LDL≥131.5 mg/dL, (“high”) | 41% | 75% | 256 | 12
| 2,217, ages 9, 13, and 16, Quebec | Parental questionnaire asking personal history of 1) high cholesterol 2) meds for cholesterol 3) heart attack, angina, 4) stroke, CVD or PVD or 5) meds for the heart; unknown family history excluded | fasting LDL≥109 mg/dL, (“borderline”) | 42% | 70% | n/a | 85
| 2,217, ages 9, 13, and 16, Quebec | Parental questionnaire asking personal history of 1) high cholesterol 2) meds for cholesterol 3) heart attack, angina, 4) stroke, CVD or PVD or 5) meds for the heart; unknown family history excluded | fasting LDL≥131.5 mg/dL, (“high”) | 51% | 69% | n/a | 19
Primrose, 1994 ^121^ | 1,012, ages 12–15, Ireland | History of stroke, angina or heart attack in either parent at any age or in 1st degree grandparents, uncles or aunts < age 55. Questionnaires completed by parents | non-fasting TC > 95th percentile according to LRC | 33% | 72% | 293 | 125
Resnicow, 1993 ^122^ | 574, elementary school age | Parental cholesterol ≥240 in 1 parent only with known and reported value by that parent | non-fasting TC > 200 mg/dL | 10% | 91% | 90 | 106
Rifai, 1996 ^62^ | 260, ages 12–20, African American-Black | Family history of early CHD or hyperlipidemia | fasting LDL > 110 mg/dL | 10% | NR | 365 | 184
Sanchez Bayle, 1992 ^123^ | 2,224, ages 2–18, Spain | Parental history of MI | fasting TC>200 mg/dL | 7% | 96% | 49 | 140
| 2,224, ages 2–18, Spain | Parental history of MI | fasting LDL>135 mg/dL | 9% | 96% | 49 | 101
| 2,224, ages 2–18, Spain | Parental history of stroke, HTN, diabetes, or hypercholesterolemia (but not MI) | fasting TC>200 mg/dL | 14% | 90% | 98 | 129
| 2,224, ages 2–18, Spain | Parental history of stroke, HTN, diabetes, or hypercholesterolemia (but not MI) | fasting LDL>135 mg/dL | 14% | 91% | 98 | 95
Shea, 1990 ^59^ | 108, ages 4–5, Hispanic, Study of Childhood Activity & Nutrition | AAP definition (maternal hypertension, diabetes, obesity, hyperlipidemia or family history of premature CHD or hyperlipidemia) | fasting TC > 170 mg/dL | 57% | 59% | 493 | 148
| 108, ages 4–5, Hispanic, Study of Childhood Activity & Nutrition | AHA and NIH Consensus Conference definition (history of hyperlipidemia or premature CHD in the child's parent, aunt, uncle or grandparent) | fasting TC > 170 mg/dL | 46% | 70% | 352 | 185
| 108, ages 4–5, Hispanic, Study of Childhood Activity & Nutrition | NCEP guidelines (history of MI or sudden death in the child's parent, aunt, uncle, or grandparent; CHD prior to age 55). | fasting TC > 170 mg/dL | 5% | 92% | 74 | 324
Steiner, 1991 ^124^ | 1,001, ages 12–21 (38% Hispanic, 15% Black, 11% Asian, 33.5% White), Kaiser population | AAP 1998 criteria (known hyperlipidemia in parent or sibling, known MI/angina, current corticosteroid use, juvenile diabetes, hypothyroidism, renal/endocrine/hepatic disease in teenager) | non-fasting TC≥200 mg/dL, repeated fasting TC if initial test≥200 mg/dL, repeated a 3rd time if more than 30 mg/dL variability between the 1st two measurements | 63% | 60% | 400 | 24
Troxler, 1991 ^125^ | 110 mostly Hispanic senior high school students | Questionnaires completed with parental assistance; family history in parents or grandparents of high cholesterol or CHD age <55 (AAP) | fastingTC > 75th percentile (4.53 mmol/L) | 38% | 79% | 218 | 245
Wadowski, 1994 ^128^ | 300 African American-Blacks, ages 2–14 | Family history of CHD in parent or grandparent at age < 55 | fasting TC > 215 mg/dL | 59% | 72% | 327 | 23

Key

* If not explicity stated, values are mixed non-fasting/fasting or not reported.

† Number eligible for screening and number missed were calculated from available data. In some cases, reported data did not allow for these calculations (these indicated with n/a).

Abbreviations

AA-Blacks=African-American Blacks, AAP=American Academy of Pediatrics, AHA=American Heart Asssociation, CHD=Coronary heart disease, CVD=Cardiovascular disease, HTN=Hypertension, LDL=Low-density lipoprotein, MI=Myocardial infarction, NCEP=National Cholesterol Education Program, NIH=National Institutes of Health, PVD=Peripheral vascular disease, TC=Total cholesterol

Definitions of a positive family history can vary, including whether grandparents are considered, the age used to define premature CHD (55, 60, or 65, or gender-based), and whether CHD in 1^st^ and 2^nd^ degree relatives is taken into account. Likewise, in these studies, multiple different definitions of family history were evaluated. A family history definition that included a parent or grandparent with CHD prior to age 50–60 and/or cholesterol >240 mg/dL had sensitivities ranging from 46–74% for TC >170 or LDL-C >130 mg/dL. ^59,^ ^117^ Parental history of early CHD alone was 5–17% sensitive for TC >170 mg/dL or LDL-C >130 mg/dL, ^59,^ ^117^ whereas parent or grandparent history of early CHD was 46% sensitive for LDL >the 95^th^ percentile. ^119^

Regardless of the precise definition, family history has been repeatedly shown to miss substantial numbers of children with elevated lipids, ranging from 17–90% overall and 30–60% in most studies. ^62,^ ^118,^ ^119,^ ^122,^ ^124,^ ^126,^ ^129^ – ^131^ In addition, the proportion of children and adolescents who qualify for screening based on family history is generally between 25–55% depending on the sensitivity of the specific family history question. ^59,^ ^62,^ ^115^ – ^119,^ ^121,^ ^124,^ ^125,^ ^127,^ ^132^ This compares with the original NCEP estimate based on LRC data that 25% of the child/adolescent population would require screening on the basis of family history.133 Studies reporting sensitivities above 70% used family history of high cholesterol, early CHD (< age 60), stroke, angina, or hypertension to detect a TC >200 mg/dL;115 family history of high cholesterol or early CHD to detect LDL ≥130 mg/dL ^117^ ; or parent or grandparent history of any risk factor (high cholesterol, diabetes, hypertension, gout, obesity) or atherosclerotic risk factor (MI, angina, sudden death, stroke or PVD) prior to age 55 to detect a fasting LDL >the 95^th^ percentile. ^119^ Of these studies with the highest sensitivity, most had poor specificity, the highest being 55%. ^117^

Obtaining family history can be time consuming and the history is often inaccurate depending on who is giving it. There is concern that African-American Black children and children from single-parent households are more likely to be missed by screening strategies that use family history. ^126,^ ^133^

## Key Question 2e. What are Other Important Risk Factors?

### Summary

Evidence for child and adolescent risk factors for dyslipidemia other than family history is strongest for overweight, but otherwise is lacking for the general population. Epidemiologic cross-sectional and cohort studies report a strong statistical association between overweight and elevations in lipids. The potential impact of incorporating weight measures into a screening tool has not been addressed. Multiple other risk factors (diet, physical inactivity, aerobic capacity/fitness, puberty and smoking) have not been evaluated adequately to assess their contribution to dyslipidemia in children or their usefulness as screening tools.

### Evidence

In addition to family history, assessment tools for selective screening could incorporate other risk factors reflecting a child's diet, physical activity level, aerobic capacity/cardiovascular fitness, overweight, and fat distribution. Childhood overweight, as measured by BMI, has been identified in one review as the best independent predictor of adult dyslipidemia after LDL-C. Its predictive power is most notable when considering increase in BMI from childhood to adulthood. ^134^

Forty-two cohort and cross-sectional studies of mixed quality with adjusted statistical analyses contributed information on additional risk factors for identifying children at increased risk for elevated lipids and/or CHD-related events (Evidence Table 2, Tables 7A, 7B, 7C). ^18,^ ^120,^ ^135^ – ^174^

Table 7a Summary of Risk Factors for Elevated Total Cholesterol in Children and Adolescents

Study | Physical Activity | Aerobic capacity/ cardiovascular fitness | Diet | Family History | Overweight or other Biological Composition Measures | Other Biological and Miscellaneous
Bonora, 1992 ^137^ | | | | | Total body fat, M: 0
Bonora, 1996 ^138^ | | | | | Total body fat, M: 0
Demerath, 2003 ^139^ | | | | | X+
DeStefano, 1995 ^140^ | | | X+ | X+ | BMI: X+* | Parent smokes: X-*
Douglas, 1996 ^141^ | | | | X+ | X+
DuRant, 1982 ^142^ | | | | Parent stroke, diabetes, obesity: X+*
| | | | Family history of diabetes, children only: O*
| | | | Family history of diabetes, adolescent only: X+*
DuRant, 1983 ^143^ | M: X+* | M: 0 | General, M: 0 | | | Smoking, M: 0
| | | Alcohol, M: 0 | | | Television watched per night, M: X+*
DuRant, 1993 ^144^ | 0 | 0
Dwyer, 1994 ^145^ | 0 | 0 | | | X-
Eisenmann, 2002 ^146^ | | | | | SSF, Adolescent, M: X+*
Freedman, 1999 ^18^ | | | | | Overweight: X+
Giovannini, 1992 ^148^ | | | | CVD: 0 | F: X+
| | | | HC parents: X+
Glassman, 1993 ^149^ | | | | | BMI, %ideal weight: X+*
| | | | | Obese: 0
| | | | | BMI in non-obese, HC: X-
Gliksman, 1993 ^174^ | | | Dietary fat, M: 0 | | BMI, M: X-
Howard, 1991 ^150^ | | | Grain: X+
Jarvisalo, 2001 ^151^ | | | | | | aIMT, cIMT, HC, DM: X+
| | | | | | cIMT: 0
Kunz, 2005 ^153^ | | | | | | Smoking, M: X-
Larsson, 1992 ^152^ | | | | FHx hyperlipidemia: X+
| | | | FHx MI/angina exclusively: 0
Macek, 1989 ^155^ | | 0
Marti, 1989 ^156^ | 0 | 0
Muhonen, 1994 ^120^ | | | | Grandfather hx, HC: X+
Resnicow, 1993 ^122^ | | | | | BMI: X+
Ribeiro, 2004 ^159^ | | | | | Body fatness: 0
Shear, 1985 ^160^ | | | | Single parental vascular disease: 0
| | | | Parent MI & parent DM or HTN: X+
Simon, 1995 ^161^ | F: 0 | F: 0
Suter, 1993 ^162^ | | | | | BMI: 0
Thorland, 1981 ^163^ | M: X+* | | 0 | | Body fatness: 0
Tolfrey, 1999 ^164^ | F: X+ | F: X+* | P-fat, F: X+* | | %Body fat, F: X+
| | | Caloric intake & TC, M: X+ | | M: 0
Tonstad, 1995 ^165^ | | | | | | Puberty stage, M: X-
Twisk, 2001 ^166^ | | Oxygen uptake: X+* | | | SSF: X+*
Twisk, 1998 ^167^ | | | | | BMI, TC: X+*
| | | | | SSF, TC: X+*
| | | | | Lean Body Mass: 0*
Twisk, 1996 ^168^ | | | P/S fat: X- | | | Smoking: X+*
| | | Cholesterol: X+
van Lenthe, 1998 ^169^ | | | | | Change in S/T, M: 0*
| | | | | F: 0
van Stiphout, 1985 ^170^ | 0 | | Coffee: 0 | TC of parents & TC of children: X+ | Age 15+: X+ | Menarche: 0
| | | | | Age <15: 0 | Age 9–16: X-
Ward, 1980 ^171^ | | | X+ | X+
Wong, 1992 ^172^ | 0 | | Extra lean/no hamburger vs lean/regular hamburger: X+ | High TC: X+ | BMI: 0 | 2–4 hours TV/day: X+
| | | | Premature MI: 0 | | Age: 0

Key

X+ positive significant relationship

X- negative significant relationship

0 no significant relationship

* TC/HDL

Abbreviations

aIMT=Abdominal aorta intima medial thickness, cIMT=Cartoid artery intima medial thickness, DM=Diabetes mellitus, Dyslip=Dyslipidemia, F=Female only, FHX=Family history, HC=High cholesterol, HDL=High-density lipoprotein, HTN=Hypertension, HX=History, M=Male only, MI=Myocardial infarction, P-fat=Polyunsaturated fat, P/M=Polyunsaturated/monosaturated fat, P/S=Polyunsaturated/saturated fat, S-fat=Saturated fat, SSF=Sum of skinfolds, S/T=Subscapular/tricep skinfold ratio, T/S=Tricep/suprailliac

Table 7b Summary of Risk Factors For Elevated LDL in Children and Adolescents

Study | Physical Activity | Aerobic capacity /cardiovascular fitness | Diet | Family History | Overweight or other Biological Composition Measures | Other Biological and Miscellaneous
Bergstrom, 1997 ^136^ | | | | | X+
Bonora, 1992 ^137^ | | | | | Total body fat, M: 0
Bonora, 1996 ^138^ | | | | | Total body fat, M: 0
DeStefano, 1995 ^140^ | | | X+ | X+
DuRant, 1982 ^142^ | | | | Parent stroke, DM, obesity, LDL/HDL: X+
| | | | FHX of stroke, LDL/HDL, children only: X-
| | | | FHX of DM, LDL/HDL, children only: 0
| | | | LDL/HDL, adolescent only: X+
| | | | Obese family member, LDL/HDL, M: 0
| | | | LDL/HDL, F: X+
DuRant, 1983 ^143^ | LDL/HDL, M: X+ | 0 | General, M: 0 | | | Smoking, M: 0
| | | Alcohol, M: 0 | | | Hours reading/day, LDL/HDL, M: X+
DuRant, 1993 ^144^ | 0 | | | | Waist/hip year 1: X+
Eisenmann, 2002 ^146^ | | | | | SSF, Adolescents, M: X+
Freedman, 1999 ^18^ | | | | | Overweight: X+
Giovannini, 1992 ^148^ | | | | HC parents: X+ | F: X+
| | | | | M: X-
Glassman, 1993 ^149^ | | | | | BMI, %ideal weight, in obese: 0*
| | | | | BMI, HC, in non-obese: X-
Gliksman, 1993 ^174^ | | | PS ratio, LDL/HDL, F: X+ | | BMI, LDL/HDL: X+
| | | Dietary fat, LDL, LDL/HDL, M: 0
Kunz, 2005 ^153^ | | | | | | Smoking, M: X-
Jarvisalo, 2001 ^151^ | | | | | | cIMT: 0
Larsson, 1992 ^152^ | | | | FHX, hyperlipidemia: X+
| | | | FHX, MI or angina exclusively: 0
Kwiterovich, 1997 ^154^ | | | Dietary cholesterol, M: X+ | | BMI at year 3: X+ | Baseline LDL: X+
| | | Any single nutrient, F: 0 | | | Tanner Stage: X-
Macek, 1989 ^155^ | | X-
Muhonen, 1994 ^120^ | | | | Grandfather hx of HC: X+
Suter, 1993 ^162^ | VLDL: X+ | VLDL: 0 | Dietary fat, VLDL: 0 | | BMI, VLDL: 0
Tolfrey, 1999 ^164^ | F: X+ | LDL/HDL, F: X+ | P-fat & LDL, F: X+ | | %Body fat, F: X+
| | | Caloric intake & LDL, M: X+
Tonstad, 1995 ^165^ | | | M: X+ | LDL & parent cholesterol, LDL & non-FH parent's cholesterol: X+ | %Body fat in those with FH mutation only: X+ | Puberty stage, M: X-

Key

X+ positive significant relationship

X- negative significant relationship

0 no significant relationship

* TC/HDL

Abbreviations

BMI=Body mass index, cIMT=Cartoid artery intima medial thickness, DM=Diabetes mellitus, F=Female only, FHX=Family history, HC=High cholesterol, HDL=High-density lipoprotein, LDL=Low-density lipoprotein, M=Male only, MI, myocardial infarction, P-fat=Polyunsaturated fat, P/S=Polyunsaturated/saturated fat, SSF=Sum of skinfolds, VLDL=Very low-density Lipoprotein

Table 7c Summary of Risk Factors for Decreased HDL in Children and Adolescents

Study | Physical Activity | Aerobic capacity /cardiovascular fitness | Diet | Family history | Overweight or other Biological Composition Measures | Other Biological and Miscellaneous
Andersen, 2003 ^135^ | | X+ | | | X+
Bergstrom, 1997 ^136^ | X+ | | Fat intake, M: X+ | | BMI: X-
Bonora, 1992 ^137^ | | | | | Total body fat, M: X+
Bonora, 1996 ^138^ | | | | | Total body fat, M: X-
Demerath, 2003 ^139^ | | | | | X-
DeStefano, 1995 ^140^ | | | X+ | X+ | BMI: X+ | Parent smokes: X-*
DuRant, 1982 ^142^ | | | | Parent stroke, DM, obesity, LDL/HDL: X+*
| | | | Family history of stroke, LDL/HDL, children only: X-
| | | | Family history of DM, LDL/HDL, children only: 0*
| | | | LDL/HDL, adolescent only: X+*
| | | | FHX obesity, LDL/HDL, M: 0
| | | | LDL/HDL, F: X+
DuRant, 1983 ^143^ | LDL/HDL, M: X+* | M: 0 | General, M: 0 | | | Smoking, M: 0
| | | Alcohol, M: 0 | | | Television watched per night: X+*
| | | | | | HDL: X-
| | | | | | Hours reading per day, LDL/HDL, M: X+
DuRant, 1993 ^144^ | | | | | SSF Year 2: X+
Dwyer, 1994 ^145^ | 0 | 0 | | | BMI: X-
| | | | | SSF: X+
Eisenmann, 2002 ^146^ | | | | | SSF, adolescent, M: X+*
| | | | | HDL, adolescent, F: X-
Freedman, 1999 ^18^ | | | | | Overweight: X-
Fripp, 1985 ^147^ | | M: X+ | | | BMI, M: X-
Giovannini, 1992 ^148^ | | | | FHX, CVD: 0 | F: X-
Gliksman, 1993 ^174^ | | | % saturated fat, PS ratio, F: X+ | | BMI: X-
| | | M: 0
Howard, 1991 ^150^ | | | High fat: X+
Kunz, 2005 ^153^ | | | | | | Smoking, M: O
Jaing, 1995 ^173^ | M: X+ | | | | SSF, change in subscapular thickness: X+ | Caucasians ages 5–17: X-
| F: 0 | | | | BMI, F: X+
Jarvisalo, 2001 ^151^ | | | | | | cIMT: 0
Larsson, 1992 ^152^ | | | | FHX MI/angina or angina exclusively, LDL/HDL: 0
| | | | Any family history: 0
Macek, 1989 ^155^ | | X+
Marti, 1989 ^156^ | 0 | 0 | | | BMI: X- | Sexual maturation, M: X-
Muhonen, 1994 ^120^ | | | | Grandfather hx of CHD: X+
| | | | Grandfather hx of high cholesterol, LDL/HDL: X+
Raitakari, 1996 ^157^ | M: X+ | | | | BMI change, F: X+
| F: 0 | | | | SSF: X+
Shear, 1985 ^160^ | | | | Single parental vascular disease: 0
| | | | Parent MI & parent DM or HTN: X+
Simon, 1995 ^161^ | F: 0 | | P/S fat, PM fat, P-fat: 0 | | SSF: X-
| | | F: X+ | | T/S SF, F: X+
Suter, 1993 ^162^ | X+ | 0 | Dietary fat: 0 | | BMI: 0
| | | | | SSF: X-
Thorland, 1981 ^163^ | M: X+* | | M: 0 | | Body fatness, M: 0
Tolfrey, 1999 ^164^ | | HDL,LDL/HDL, F: X+* | P-fat, F: X+*
Tonstad, 1995 ^165^ | | | | HDL & FH parent HDL: X+ | | Puberty stage, M: X-
Twisk, 2001 ^166^ | | Oxygen uptake X+* | | | SSF
| | | | | X+*
Twisk, 1998 ^167^ | | | | | BMI: 0
| | | | | SSF: 0
| | | | | Lean Body Mass: 0
Twisk, 1996 ^168^ | X+ | | Alcohol: X+ | | | Smoking: X-
van Lenthe, 1998 ^169^ | | | | | S/T, M: X-
| | | | | Change in S/T, F: 0
| | | | | Change in TC/HDL, M: 0
van Stiphout, 1985 ^170^ | | | | | Age 15, M: X-

Key

X+ positive significant relationship

X- negative significant relationship

0 no significant relationship

* TC/HDL

Abbreviations

BMI=Body mass index, CHD=Coronary heart disease, cIMT=Cartoid artery intima medial thickness, CVD=Cardiovascular disease, DM=Diabetes mellitus, F=Female only, FHX=Family history, HDL=High-density lipoprotein, HTN=Hypertension, LDL=Low-density lipoprotein, M=Male only, MI=Myocardial infarction, P-fat=Polyunsaturated fat, P/M=Polyunsaturated/monosaturated fat, P/S=Polyunsaturated/saturated fat, SSF=Sum of skinfolds, S/T=Subscapular/tricep skinfold ratio, T/S=Tricep/suprailliac, SF=Saturated fat

Thirty studies examined overweight or body fat composition measures as a risk factor ^18,^ ^135^ – ^141,^ ^144^ – ^149,^ ^154,^ ^156^ – ^159,^ ^161^ – ^167,^ ^169,^ ^170,^ ^172,^ ^174^ and it was the most consistently effective in predicting risk of dyslipidemia compared to other factors assessed.

Six studies evaluated overweight as a risk factor along with family history. ^140,^ ^141,^ ^148,^ ^165,^ ^170,^ ^172^ Italian school girls (n=361) who were overweight, defined as weighing ≥ 20% ideal weight, had higher mean LDL-C (126.6 mg/dL for overweight vs 99.5 for those not overweight mg/dL, p<0.001) and mean TC (173.8 mg/dL vs 199.0 mg/dL, p<0.01) with lower mean HDL-C (58.9 mg/dL vs 50.0 mg/dL, p<0.001). ^148^

Among 506 inner-city youths aged 5 to 19 who were predominantly African American and Hispanic, those who were overweight had a 1.74 odds ratio for having hypercholesterolemia controlling for age and family history (95% CI=1.34–2.14). ^141^ Sensitivity of using this overweight measure alone to screen was 42%, with a specificity of 71% for predicting hypercholesterolemia (TC > 170 mg/dL or LDL-C > 110 mg/dL). Combining overweight with family history had a sensitivity of 49% and specificity of 64%. ^141^

A Wisconsin study of 2,726 schoolchildren aged 5 to 15 showed BMI was related to adverse levels of all lipids and lipoproteins (TC: r= 0.010 [95% C.I. 0.002, 0.018], LDL-C: r= 0.012 [95% C.I. 0.004, 0.019], HDL-C: r= -0.013 [95% C.I. -0.016, -0.010]). ^140^ In contrast, a study of 1,081 youths aged 2 to 20 in a pediatric office-based cholesterol screening program showed BMI was not associated with cholesterol level. ^172^ A study of 458 youths in a suburban Dutch community found that for girls over age 15, TC increased step-wise across quartiles of body weight with the 4th quartile showing a significant difference from the 1^st^ quartile of approximately 7mg/100ml (p<0.05). ^170^ A multiple regression analysis of 164 highly-selected youths aged 6–16 with heterozygous FH showed that LDL-C was related to FH parent's cholesterol levels, percent body fat, pubertal stage, and non-FH parent's cholesterol level (p<.01), together explaining 40% of variance in LDL-C (CI 25%–55%). ^165^

## Key Question 2f. What are Effective Screening Strategies for Children/adolescents (Including Frequency of Testing, Optimal Age for Testing)?

### Summary

Currently recommended screening strategies have limited diagnostic accuracy, low adherence to guidelines by providers, and limited compliance by parents and children. No trials compare strategies of screening in children, address the frequency and optimal age for testing, or evaluate strategies that might increase provider and parent compliance.

### Evidence

Twenty-six studies evaluated screening strategies among children in various settings (Evidence Table 3). ^59,^ ^62,^ ^79,^ ^115,^ ^117^ – ^120,^ ^122,^ ^124,^ ^126,^ ^130,^ ^131,^ ^133,^ ^175^ – ^186^ One RCT of college students compared two regimens for screening; ^183^ all others were non-comparative prospective studies describing screening interventions. Two additional studies addressed parent and physician response to screening results. ^187,^ ^188^ These and others reported low parental compliance with follow-up testing, even when follow-up was free, as with prepaid health plans.

Studies demonstrate low compliance among primary care physicians in following current guidelines for screening. ^188^ In an ancillary study of the Child Adolescent Trial for Cardiovascular Health (CATCH), parents were given recommendations to consult their child's physician if TC exceeded 200 mg/dL on one or more occasion. ^187^ After physicians saw the children, only 59% were further evaluated for possible elevated cholesterol. Of these, half of the physicians repeated cholesterol tests, 42% asked about family history, 38% made recommendations for dietary management, and only 12% referred children to dietitians. ^187^

#### Neonatal screening

Neonatal screening for dyslipidemia has been examined in multiple studies, mostly using cord blood for analysis of TC ^106,^ ^189^ – ^202^ Other studies have investigated the use of dried filter paper blood spots from cord blood ^203^ and from heel sticks taken from 3–7 day old infants (the same samples used for routine neonatal screening for conditions such as hypothyroidism and phenylketonuria). ^204^ – ^209^ Five studies had follow-up of cord blood cholesterol levels with serum levels in the children at a later time. ^190,^ ^192,^ ^193,^ ^196,^ ^197^ One study included serum analysis at birth and 1 year, along with LDL receptor mutation testing of infants with parents who had DNA-documented heterozygous FH, comparing levels in affected newborns to non-affected newborns. ^210^ Using cord blood, TC and LDL-C levels were elevated in the FH newborns as compared to non-FH newborns, but there were no significant differences between HDL-C or TG. However, differences between FH and non-FH infants in TC and LDL-C were more pronounced when measured at 1 year. ^210^ No studies were identified that screened a general population of infants and followed up abnormal results with mutation analysis.

## Key Question 3. What are the Adverse Effects of Screening (Including False Positives, False Negatives, Labeling)?

### Summary

Parental non-compliance with screening and follow-up recommendations is reported to be related to concerns about test accuracy, lack of proof that intervention makes a difference in children, concerns about upsetting the child, refusal by the child, inconvenience, or decisions to institute a diet themselves and have child rechecked subsequently.

### Evidence

Potential adverse effects of screening for dyslipidemia among children have been examined in one randomized controlled trial ^211^ and five studies of various other designs ^130,^ ^212^ – ^215^ Screened college students were randomized to receive desirable results (TC = 174 mg/dL) or borderline-high results (TC = 224 mg/dL). Those who received borderline-high test results rated high cholesterol as a less serious threat to health than did the desirable-feedback subjects, and perceived the test to be less accurate. Higher self-esteem was associated with lower likelihood of requesting information after receiving borderline-high test results. ^211^

Parental non-compliance with screening has been demonstrated by two studies of screening. The Child and Adolescent Trial for Cardiovascular Health (CATCH) program measured cholesterol levels in 5,106 children in 3^rd^ grade and in 3,936 of these again in 5^th^ grade. Parents received mailed notification of their children's cholesterol results and a follow-up telephone survey. Parents indicated that a physician had been consulted for only 20% of children. Eighty-four percent of those notified once recalled receiving the notice, yet only 39% of those remembered the results as being high. ^187^

Likewise, a pediatric group screened 439 children ages 2–15 as part of well-child exams or non-acute illness including siblings of all those seen. Of the 134 (31%) children who had cholesterol levels above the 75^th^ percentile and were recommended to return for a fasting lipid panel, 51% did so. Parents of children who did not return were contacted 4–6 months later, and 94% remembered their child's screening cholesterol level had been elevated, while 64% remembered that follow-up had been suggested. The most common reason parents provided for lack of timely follow-up were concerns about whether the test was accurate (67%), planning to recheck at next visit (67%), concern that child was upset by initial finger stick (47%, most of whom were parents of children younger than 5 years), lack of proof that intervention for high cholesterol makes a difference in children (40%), inconvenience (40%), and decision to try a low-fat, low-cholesterol diet before having the child's lipids rechecked (40%). Family history of hypercholesterolemia, angina, and stroke were not consistently associated with higher follow-up. ^130^

Identification of dyslipidemia in children was associated with increased parental reporting (not confirmed with objective measures) of behavior disturbances in the subsequent 12 months, worse scores on the child behavior checklist, but no differences in depression or anxiety for either the children or the mothers. ^213^ Children with dyslipidemia (n=36) and matched controls from one large pediatric practice showed no differences measures of well-being, depression and behavior. ^215^ Older dyslipidemic children (ages 6–10) had more negative health beliefs than younger children (ages 4–6), and younger children's reports of parent's dietary control were negatively related to the children's feelings of acceptance. ^212^ Parents of children diagnosed with FH reported perceptions of burdensome follow-up causing conflicts between themselves and their children, and difficulty changing diet. Although the older children interviewed as part of this study tended to remember feeling sad, angry, or worried about heart problems, none reported that these worries interfered with their usual activities. ^214^ Children with greater problem solving skills have demonstrated better compliance with recommended diet and greater reductions in LDL-C following traditional diet counseling. ^216^

Limitations of the literature around adverse effects of screening include small sample sizes, mostly observational studies, and the hypothetical nature of risks in the screened populations.

## Key Question 4. In Children/adolescents, What is the Effectiveness of Drug, Diet, Exercise, and Combination Therapy in Reducing the Incidence of Adult Dyslipidemia, and Delaying the Onset and Reducing the Incidence of CHD-related Events (Including Optimal Age for Initiation of Treatment)?

No studies meeting inclusion criteria evaluated the effect of a childhood intervention on the incidence of adult dyslipidemia, or the onset or incidence of CHD-related events and outcomes.

## Key Questions 5 – 8. What is the Effectiveness of Drug, Diet, Exercise, and Combination Therapy for Treating Dyslipidemia in Children/adolescents?

### Summary

Statins and bile acid binding resins are effective for reducing TC and LDL-C in children with FH, the only population for whom they have been studied. These trials might not generalize to children without FH. Trials of other agents are methodologically limited. Diet supplements (psyllium, oat, sterol margarine) and counseling are marginally effective in lowering lipid levels in children with FH or FCH, as well as in children with idiopathic (risk factor associated) dyslipidemia. Trials show minimal if any improvement in lipids with exercise among children from the general population (overweight or normal weight). No trials evaluate exercise treatments in children with FH.

### Evidence

Forty randomized controlled trials met inclusion criteria and are included in this report (Evidence Table 4). ^37^ – ^41,^ ^66^ – ^69,^ ^71^ – ^78,^ ^80^ – ^82,^ ^217^ – ^236^ Of these, ten are rated good quality, ^37,^ ^38,^ ^40,^ ^69,^ ^71,^ ^76,^ ^78,^ ^218^ – ^220^ 12 fair, ^41,^ ^66,^ ^67,^ ^72,^ ^74,^ ^81,^ ^221,^ ^222,^ ^225,^ ^232,^ ^233,^ ^235^ and 18 poor. ^39,^ ^68,^ ^73,^ ^75,^ ^77,^ ^80,^ ^82,^ ^217,^ ^223,^ ^224,^ ^226^ – ^231,^ ^234,^ ^236^ Drug therapy interventions included bile acid binding resins, anti-oxidants (vitamin C and E), docosahexaenoic acid (DHA), HMG-CoA Reductase Inhibitors (statins), and combination therapy. Studies of other types of interventions included exercise therapy and advice, dietary products (margarine, flour, cereal, garlic extract), dietary advice, and combinations of these. Major limitations include 20 or fewer subjects in each arm, ^39,^ ^67,^ ^73,^ ^82,^ ^221,^ ^223,^ ^224,^ ^230,^ ^234^ – ^236^ high loss to follow-up, ^77,^ ^81,^ ^222^ lipid measures that are non-standardized or not reported as such, varied inclusion criteria (Table 4B), failure of blinding, ^77,^ ^220,^ ^228,^ ^231^ – ^233^ lack of results presented for the period prior to crossover, ^39,^ ^41,^ ^73^ – ^75,^ ^223,^ ^224,^ ^227,^ ^234,^ ^236^ and lack of intention to treat analyses. ^41,^ ^66,^ ^67,^ ^72,^ ^75,^ ^77,^ ^81,^ ^82,^ ^217,^ ^222,^ ^224,^ ^226,^ ^228,^ ^229,^ ^231^ – ^233^ In addition, one trial did not report data for the placebo group. ^66^

Statins, bile-acid binding resins, and fibrates have been tested only in children with FH and FCH. Applicability of results from these trials to children without these conditions may be difficult. We assessed external validity for each study using the following criteria: population-based (vs recruited from a lipid clinic), presence of a run-in period, number of participants, and reimbursement for participants. Eleven studies were population-based, ^67,^ ^69,^ ^72,^ ^78,^ ^219^ – ^222,^ ^225,^ ^230,^ ^233^ while others used populations recruited from single lipid clinics. ^37,^ ^39^ – ^41,^ ^66,^ ^68,^ ^73^ – ^77,^ ^80,^ ^82,^ ^223,^ ^224,^ ^226,^ ^231,^ ^237^ Fourteen reported the presence of a run-in period, ^37,^ ^39^ – ^41,^ ^66,^ ^67,^ ^69,^ ^71^ – ^76,^ ^78,^ ^80,^ ^82,^ ^223,^ ^224,^ ^228,^ ^234^ – ^236^ one of which did not exclude any participant after the run-in period. ^66^ Five trials failed to report or were unclear about the presence of a run-in period. ^227,^ ^229^ – ^231,^ ^238^ Three studies reported reimbursement or free medication for participants; ^75,^ ^225,^ ^226^ others did not mention this. Only 24 studies had 50 or more participants. ^37,^ ^381,^ ^40,^ ^66,^ ^68,^ ^69,^ ^71,^ ^72,^ ^76,^ ^78,^ ^80,^ ^81,^ ^217^ – ^220,^ ^222,^ ^225^ – ^229^ ^232,^ ^233^ Pharmaceutical or cereal company funding was reported in 14 studies; 16 other studies did not report funding source.

#### Studies in children with probable or definite familial hypercholesterolemia

Drug treatment. Eighteen trials meeting inclusion criteria evaluated drug therapies for treatment of children with probable or definite heterozygous familial hypercholesterolemia (Table 8). ^37,^ ^38,^ ^66,^ ^68,^ ^69,^ ^71^ – ^76,^ ^78,^ ^80^ – ^82,^ ^224,^ ^234,^ ^236^ Most of these studies included children who were already compliant with a recommended low-fat, low-cholesterol diet. These diets are presented in Table 1. Both treatment and control groups were maintained on the diet during these trials.

Table 8 Randomized Controlled Trials of Drug Treatment for Children with Identified Familial Hypercholesterolemia or Other Monogenic Dyslipidemia

Author, year | Drug | Population | Duration of Trial | Baseline Diet | Results | | Quality Rating
| | | | | Between Group Differences | Within Group Differences
Statins
Clauss, 2005 ^38^ | Lovastatin 20 mg/day for 1st 4 weeks then 40 mg/day for remaining 20 weeks vs. placebo | n=54, girls ages 10–17, all post-menarchal | 24 weeks | NR | Total cholesterol, LDL, and Apo B were significantly lower after 4 wks (on 20mg) and after 24 wks (on 40mg) compared to placebo. At 24 wks, mean % changes from baseline were: TC: 26.8% for lovostatin vs +5.2 for placebo (p<0.001); LDL: -21.8 for lovastatin vs +4.5 for placebo (p<0.001). | | Good
Couture, 1998 ^66^ | Simvastatin 20 mg/day vs. placebo | n=63 | 6 weeks | AHA Phase 1 diet | Total cholesterol, LDL, and total ApoB levels were significantly lowered by treatment (vs. placebo) at all time measurements (p<0.0001). | | Fair
| | | | | HDL levels increased in all groups with drug vs. placebo (p=0.003 to 0.30).
| | | | | TG levels decreased (p=0.009 to 0.10).
de Jongh, 2002 ^68^ | Simvastatin 10 mg/day, doubled every 8 weeks up to 40 mg/day vs. placebo | n=50, ages 9–18 | 28 weeks | NR | Mean absolute change in FMD was higher for treatment group vs. placebo (p=0.05). | Treatment group had reductions in mean TC (p=0.0001), LDL (p=0.0001) and TG (p=0.041). | Poor
| | | | | TC, LDL and TG were all reduced for treament group vs. placebo (p=0.0001, p=0.0001 and p=0.04 respectively). | No significant changes in lipoproteins for placebo group compared with baseline.
| | | | | | FMD increased in the treatment group (p<0.0001) and did not change in the placebo group.
de Jongh, 2002 ^69^ | Simvastatin 10 mg/day titrating up to 40 mg/day vs. placebo | n=173, ages 10–17 | 48 weeks of intervention after 4 week run-in | NR | TC and LDL-C, ApoB, and VDL-C reduced at all time points by drug vs. placebo (p<0.001). | | Good
Knipscheer, 1996 ^71^ | Pravastatin in 3 active drug groups: 5, 10, or 20 mg/day vs. placebo | n=72 | 12 weeks, following an 8 wk diet and placebo run-in period. | Carbohydrates 50% of energy, protein 20%; and fat 30%; unsaturated: saturated ratio of 2:1; total cholesterol <300 mg/day | TC, LDL and ApoB100 were significantly reduced in all pravastatin treated groups compared with placebo (p<0.05 for both). | TC, LDL and ApoB100 were significantly reduced in all pravastatin treated groups compared with baseline (p<0.05). | Good
| | | | | HDL increases and TG changes were not significantly different from placebo. | HDL increases and TG changes were not significantly different from baseline .
Lambert, 1996 ^72^ | Lovastatin at 10, 20, 30, or 40 mg/day (4 active drug groups, no placebo) | n= 69, boys age ≤ 17 | 8 weeks | Patients counseled by dietician throughout the trial; fat 30% total calories, saturated fat <10%, polyunsaturated fats <10%, cholesterol <125 mg/100 kcal/day or <300 mg/day (whichever less). | Demonstrated a dose response relationship, with improved results up to a dose of 30 mg/day. | All doses reduced total cholesterol, LDC, and ApoB (P ≤ .0001 for all). | Fair
McCrindle, 2003 ^76^ | Atorvastatin 10 mg/day vs. placebo | n=187, ages 10–17 | 26 weeks | NCEP Step 1 diet | TC, LDL-C, TG and ApoB were reduced compared to placebo (p<0.001 for TC, p<0.001 for LDL-C, p=0.03 for TG, p<0.001 for apoB). | Reductions in TC, LDL and TG and increase in HDL were significant for simvastatin group. | Good
| | | | | HDL cholesterol increased for treatment vs. placebo (p=.02). | No significant improvements in placebo group.
Stein, 1999 ^78^ | Lovastatin starting at 10mg/day, titrating to 40 mg/day vs. placebo | 132 boys, ages 10–17 | 48 weeks | AHA pediatric diet | TC and LDL-C decreased at all dosages (p<.001). About 6% additional LDL-C lowering occurred with each doubling of lovastatin dosage. | | Good
| | | | | No significant changes in HDL-C or triglycerides compared to placebo.
Wiegman, 2004 ^83^ | Pravastatin 40 mg/day vs. placebo | 214 ages 8–18 | 2 years | Instructed to continue a fat restricted diet | TC decreased for pravastatin vs. placebo (56% vs 2%, p<0.001) | | Good
| | | | | LDL decreased 57% for pravastatin vs 0% for placebo 9<0.001)
| | | | | No significant differences for HDL or placebo.
| | | | | Carotid IMT decreased for pravastin vs. placebo (p=0.02)
Bile-acid Resins
McCrindle, 1997 ^74^ | Cholestyramine 8 gm/day as pills vs. powder (no placebo) | n=40, ages 10–18 | 8 weeks each cross-over period | AHA Step II diet | No lipid levels reported prior to cross-over. | Reduction in LDL for both pills (p=0.006) and powder (p=0.0001) with no significant difference between forms (p=0.16). | Fair
| | | | | At end of study, 82% preferred pill, 16% powder, and 2% neither form. Mean compliance was greater for pills (p=0.01).
McCrindle, 2002 ^75^ | Colestipol (5 g/day) + pravastatin 10 mg/day vs. colestipol alone (10g/day) | n=40, ages 8–18 | 18 weeks each cross-over period | AHA Step II diet | No data reported prior to cross-over. | Reductions in TC and LDL seen with both colestipol only and colestipol plus pravastatin. | Poor
Tonstad, 1996 ^80^ | Colestipol 10 gm/day or 5 gm twice daily vs. placebo | 66 adolescents | 8 weeks | NCEP diet: fat ≤30% of calories, saturated fat <10%, cholesterol <200 mg/day. | TC and LDL decreased for treatment group vs. placebo (p<0.01 for both). HDL and TG were not signficantly different. | | Poor
Tonstad, 1996 ^81^ | Cholestyramine titrating up from 4 gm/day to 8 gm/day vs. placebo | 96 boys ages 6–11 | 1 year | NCEP diet: fat ≤30% of calories, saturated fat <10%, cholesterol <200mg/day. | At 1 year: | | Fair
| | | | | TC decreased 11.5% in treatment vs 3% in placebo (p<0.001)
| | | | | LDL decreased 18.6% in treatment group vs. 1.5% in the placebo group (p<0.0001).
| | | | | No changes in HDL or TG.
Fibrate
Wheeler, 1985 ^82^ | Bezafibrate 10–20 mg/kg/day twice daily vs. placebo | 14 | 3 months each cross-over period | Low saturated fat, increased polyunsaturated fat; actual total fat intake of 98g/day (range: 44–148 gm/day) | No data reported prior to cross-over. | Mean plasma TC decreased during bezafirate treatment (p<0.0001) | Poor
| | | | | | Mean HDL increased (p<0.01).
| | | | | | No change in TG.
Other
Engler, 2003 ^224^ | Vitamin C 250 mg twice daily vs. Vitamin E 200 IU twice daily vs. placebo | n=15, ages 8–21 | 6 weeks each cross-over period | Food guide pyramid and NCEP II guidelines | No data given prior to cross-over. | NCEP II diet resulted in an 8% reduction in LDL (p<0.01) from baseline. No other significant differences in lipid levels. | Poor
| | | | | | Brachial artery FMD improved compared with baseline (p<0.001) in response to diet plus anti-oxidants.
Engler, 2004 ^234^ | Docosahexaenoic acid vs. placebo | 20 children ages 9–19 | 6 weeks each cross-over period, with 6 week wash-out | NCEP II | No data reprted prior to cross-over. | For combined groups, FMD decreased significantly from baseline for both DHA and placebo groups. | Poor
| | | | | | TC, LDL and HDL increased significantly from baseline for DHA group, but not for placebo group.
Engler, 2005 ^234^ | Docosahexaenoic acid vs. placebo | 20 children ages 9–19 | 6 weeks each cross-over period, with 6 week wash-out | NCEP II | No data reported prior to cross-over. | For combined groups, there were no significant differences in TC, LDL, HDL or triglycerides. The DHA +diet group had lower LDL subfractions (LDL1 and LDL 3) and higher HDL2 compared to placebo + diet. | Poor
Malloy, 1978 ^236^ | p-Amnosalicylic acid 150 mg/kg/day up to 8 g/day vs. placebo | 20 children ages 5–21 | 6 months each cross-ver period | Restricted in cholesterol (<200 g/day) and saturated fat (<20% of total calories); all participants and parents received monthly dietary counseling | No data reported prior to cross-over. | Mean TC was lower for treatment with diet and PAS-C vs. diet alone (p<.001). | Poor
| | | | | | Mean fasting serum triglyceride levels decreased 15.7% with PAS-C plus diet (p<.001). Levels in the compliant subgroup were not lower than those of other patients.
| | | | | | No difference in HDL with drug treatment.

Abbreviations

AHA=American Heart Association, ApoA=Apolipoprotein A, ApoB=Apolipoprotein B, DHA=Docosahexaenoic acid, FMD=Flow-mediated dilation, HDL=High-density lipoprotein, HDL-C=High-density lipoprotein cholesterol, IMT=Intima medial thickness, LDL=Low-density lipoprotein, LDL-C=Low-density lipoprotein cholesterol, NCEP=National Cholesterol Education Program, NR=Not reported, PAS-C=P-aminosalicylic acid-cholesterol, TC=Total cholesterol, TG=Triglycerides, VDL-C=Very low-density Lipoprotein cholesterol

All the trials of statin drugs, including one trial of atorvastatin, ^76^ three of lovastatin, ^38,^ ^72,^ ^78^ two of pravastatin ^37,^ ^71^ and three of simvastatin, ^66,^ ^68,^ ^69^ demonstrated improvement in TC and LDL-C among children and adolescents with FH. The decrease in TC ranged from -17% to -32% compared to baseline for treatment groups vs. changes of +3.6% to -2.3% for placebo. The decreases in LDL-C ranged from -19% to -41% for treatment groups, vs. changes of +0.67% to -3% for placebo. HDL-C decreased in the one trial of atorvastatin, ^76^ increased in one ^72^ but not the other trial of lovastatin, ^78^ did not change in the one trial of pravastatin that reported HDL-C, ^71^ and increased in two trials of simvastatin ^66,^ ^68^ but not the third. ^69^ Overall, HDL-C increased between +1% and +11% for treatment groups, vs. -1% to +4.8% for placebo groups. Triglyceride changes varied, with only simvastatin demonstrating lower triglycerides in all three trials that evaluated it. ^66,^ ^68,^ ^69^ Overall, the range of triglyceride change with treatment was +9% to -24%, vs. placebo +4% to -12%.

Results from eight trials of statins, six good, ^37,^ ^38,^ ^69,^ ^71,^ ^76,^ ^78^ one fair, ^66^ and one poor ^68^ quality, were included in a meta-analysis (Figures 7–9). Data from studies reporting triglyceride outcomes were not sufficient for meta-analysis. Pooled estimates for all doses combined included 24.4% (95% C.I. 19.5, 29.2) mean reduction in TC, 30.8% (95% C.I. 24.1, 37.5) mean reduction in LDL-C, and 3.3% (95% C.I. 1.0, 5.7) mean increase in HDL-C. Using drug-adjusted equivalent doses showed linear relationships between dose and drug effect as well as between dose and mean age of the study participants (lower doses associated with younger age, p=0.90, p=0.0029). Other study level covariates, such as duration and percent male or female, were not associated with drug effects. Exclusion of the poor quality study did not affect the results.

Figure 7. Meta-Analysis of Statin Trials in Children With Familial Hypercholesterolemia: Total Cholesterol Reduction

Figure 8. Meta-Analysis of Statin Trials in Children With Familial Hypercholesterolemia: LDL-C Reduction

Figure 9. Meta-Analysis of Statin Trials in Children With Familial Hypercholesterolemia: HDL-C Increase

One fair quality trial of cholestyramine ^81^ and one poor quality trial of colestipol ^80^ demonstrated decreased total cholesterol and LDL-C but no change in HDL-C or triglycerides. One fair quality study without pre-crossover results demonstrated that patients ages 10–18 preferred and were more compliant with a pill form vs. powder form of cholestyramine. ^74^

Poor quality trials evaluating bezafibrate, ^82^ vitamins C and E, ^224^ DHA, ^234,^ ^236^ p-aminosalicylic acid, ^73^ and a head-to-head comparison of combined colestipol and pravastatin vs. colestipol alone, ^75^ failed to report pre-crossover data. Trials of vitamin C and E and DHA included children and adolescents with FH as well as FCH.

Non-invasive measures of vascular outcomes were evaluated in one good quality study that showed regression of mean carotid intima-media thickness (IMT) over two years with treatment with pravastatin, ^37^ and in two poor quality trials without pre-crossover data that showed improvement in brachial artery flow-mediated dilation with vitamins C and E treatment, and DHA. ^224,^ ^234^

Diet treatment. Of the five trials meeting inclusion criteria that evaluated diet treatments in children with FH (Table 9), one was rated good quality, ^40^ three fair, ^41,^ ^67,^ ^235^ and one poor. ^39^ These trials evaluated plant sterol margarines vs. placebo margarine, ^39^ – ^41^ , psyllium-enriched cereal, ^67^ and garlic extract. ^235^ Although all three trials of sterol margarines were crossover trials without pre-crossover results presented, the wash-out periods between treatment periods were 4–6 weeks in two of these trials, making it more likely that the results of these trials are valid. ^40,^ ^41^ For these two studies, the mean decreases in TC were -7.4% to -11%, the decreases in LDL-C were -10% to -14%. The differences in HDL-C and triglyceride levels were not significant. The third trial of sterol margarine had no washout period between the treatment arms, but showed similar results (-11% change in TC, -15% for LDL-C, non-significant changes for HDL-C and TG). ^39^ The trial of psyllium-enriched cereal found a 8% decrease in TC in the treatment group vs. -3% in the placebo group, and a decrease in LDL-C of -10% in the treatment group vs. -0.5% in the placebo group, with non-significant post-crossover results for both HDL-C and TG. ^67^ There was no significant improvement in lipid levels with 8 weeks of garlic extract treatment. ^235^

Table 9 Randomized Controlled Trials of Diet Treatment for Children with Identified Familial Hypercholesterolemia or Other Monogenic Dyslipidemia

Author, year | Intervention(s) | Population | Duration of Trial | Results | | Quality Rating
| | | | Between Group Comparisons | Within Group Comparisons
Amundsen, 2002 ^41^ | Plant sterol spread vs. Control spread | 38 children | 8 weeks each period | No data reported prior to cross-over. | Results combined indicate: TC, LDL, Apo B were decreased for treatment group vs. control. No change in HDL, TG, or Apo A-1. | Fair
Davidson, 1996 ^67^ | 58 gram psyllium-enriched cereal vs. placebo cereal | 32 children aged 6 – 18 within the Chicago area | 6 weeks each period of cross over | No data reported prior to cross-over. | At 6 weeks: | Fair
| | | | | TC decreased 8% in psyllium group (p=0.05) vs 3% for placebo (NS).
| | | | | LDL cholesterol decreased 10% in psyllium group (p=0.001) vs 0.5% in placebo group (NS).
| | | | | Response to treatment differed between subjects consuming psyllium during period 1 vs period 2. A period-by-time interaction was found for total cholesterol (p=0.02).
Gylling, 1995 ^39^ | Rapeseed oil-rich margarine with sitostanol ester vs. Rapeseed oil-rich margarine without sitostanol ester | 14 children with HeFH (mostly established by DNA) 7 each group | 6 weeks each arm cross over | No data reported prior to cross-over. | TC decreased 11% in sitostanol group vs 0.8% in placebo group (p<0.05). | Poor
| | | | | LDL 18% decreased in sitostanol group vs 3% in placebo group (p<0.05).
| | | | | No change in HDL or TG.
de Jongh, 2003 ^40^ | Sterol-enriched margarine, (15g/day) vs. Identical appearing control spread, non-sterol-enriched (15g/day) | 41 prepubertal HeFH, ages 5–12 | 4 weeks each period cross over | Last 4 weeks: TC and LDL were decreased significantly for sterol group vs placebo (p<0.001 for both). No difference in HDL, TG, or FMD for sterol vs. placebo. | | Good
McCrindle, 1998 ^235^ | 300 mg tablet of garlic extract (Kwai, Lichtwer Pharma, Berlin, Germany) containing 0.6 mg of allicin placed in a gelatin capsule with inert filler vs identical capsule with gelatin filler only. | 30 children with FH, ages 8–18 | 8 weeks | Relative to placebo, garlic treatment resulted in: | | Fair
| | | | TC increase 0.6 mmol/L (p=0.86)
| | | | LDL-C decrease 0.5mmol/L, p=0.90
| | | | HDL increase 9.3 mmol/L, p=0.29
| | | | TG decrease 0.72 mmol/L, p=0.70.

Abbreviations

ApoA-1=Apolipoprotein A-1, ApoB=Apolipoprotein B, FH or HeFH=Familial hyperlipidemia, FMD=Flow mediated dilation, HDL=High-density lipoprotein, LDL=Low-density Lipoprotein, LDL-C=Low-density lipoprotein cholesterol, NS=Not significant, TC=Total cholesterol, TG=Triglycerides

Exercise treatment. No studies meeting inclusion criteria evaluated exercise treatment for lipid lowering in children with FH.

#### Studies in children with elevated lipids, but not meeting criteria for familial hypercholesterolemia

Drug treatment. No studies meeting inclusion criteria evaluated drug interventions in children without monogenic dyslipidemia.

Diet treatment. Dietary interventions in general populations of children and adolescents were addressed in eight studies, three of good quality, ^218^ – ^220^ and five of poor quality (Table 10). ^77,^ ^223,^ ^227,^ ^229,^ ^231^ Two of the good quality studies were from the multi-center Dietary Intervention Study in Children trial. ^218,^ ^219^ These and other trials ^77,^ ^227^ tested the effect of dietary advice for families and children on dietary outcomes and lipid levels. A good quality trial by the DISC Collaborative Research Group showed that intensive counseling and follow-up over three years reduced TC and LDL-C and improved dietary intake. ^219^ Lipid lowering results were not sustained at five and seven year follow-up, after the intervention ceased, but improvements in diet remained significant. ^218^ One good quality study of the Parent-Child AutoTutorial (PCAT) program ^220^ reported 8% improvement in LDL-C (p<0.05) compared to the at-risk control group. Another poor quality study of PCAT found decreases in both treatment and control groups, but no between-group differences. ^77^ A poor quality study of single vs. multiple nutritional advice sessions found 7–8% decreases in TC and LDL-C for the multiple session group, vs. 3% decrease in TC in the single session group. ^227^

Table 10 Randomized Controlled Trials of Diet Treatment for Children Without Identified Familial Hypercholesterolemia or Other Monogenic Dyslipidemia

Author, year | Intervention(s) | Control | Population | Duration of Trial | Results | | Quality Rating
| | | | | Between Group Comparisons | Within Group Comparisons
Dennison, 1993 ^223^ | Psyllium cereal (3 g of water-soluble fiber and 3 gm of water-insoluble fiber per serving). Two 28 gm servings per day. | Placebo cereal with 5 gm of water-insoluble fiber. Two 28 gm servings per day. | 25 children ages 5–17 with LDL>110 mg/dL after diet treatment 12 each group | 4–5 weeks each period with a 2 week wash-out. | | No pre cross-over results given. | Poor
| | | | | | No difference for changes in TC, HDL or LDL.
| | | | | | TG increased less for psyllium group vs. control (p<0.05).
DISC Collaborative Research Group, 1995 ^219^ | Family oriented behavioral intervention to promote dietary adherence. Sessions weekly × 6 weeks, then biweekly × 10 weeks, plus 2 individual visits for children with family members. In second 6 months: 4 group and 2 individual sessions. Years 2 and 3: group individual and maintenance sessions held 4–6 × per year with monthly phone contacts as needed. Used motivational interviewing and stages of change. | Usual care: Public educational publications on heart-healthy eating provided. Parents informed if child blood cholesterol high - no specific recommendations to see physician given. 3-year lipid results provided, with referral as clinically warranted. | 663 prepubertal boys and girls, ages 8–10 | 3 years | TC decreased for diet group vs. control in year 1 (p=0.03) and year 3 (p=0.04) . | | Good
| | | | | LDL decreased in the diet group vs. control at 1 and 3 years (p<0.001 and p=0.02).
| | | | | HDL decreased in diet group vs. control between groups at year 1 (p=0.03) but not year 3 (p<0.75).
| | | | | No significant differences between groups for TG at years 1 or 3.
| | | | | Dietary total fat, saturated fat, and cholesterol intakes were lower in the diet group vs. control
Gold, 1991 ^231^ | Oat bran supplemented cereal within AHA Step 1 diet | Control cereal within AHA Step 1 diet | 49 school age children with TC>185 mg/dL | 4 weeks | No significant differences between groups in total cholesterol, LDL, HDL, TG or Apo A. Intervention group had decreased ApoB (-9mg/dL) vs. control (2mg/dL), p=0.05. | | Poor
Kuehl, 1993 ^227^ | MSI= four 90 minute sessions with focus on food preparation. Participants received notebooks with nutrition information and recipes, incentives for attendance and completion of behavioral contracts (eating low fat meal) Multi-session intervention. | SSI=one 90 minute nutrition education session for pt, siblings and parents (slides presentation, low fat food prep and tasting, distribution of fruit and cereal). “Returned for subsequent food sampling with nutritionist present” but no further formal education. Single session intervention. | 295 children ages 2–15 with TC ≥185 | 16 weeks | | Both groups had improvement in TC from baseline to the 16-week visit (no results given for between group comparison). MSI group also had significantly decreased LDL. | Poor
| | | | | | Both groups had a significant decreases in the proportion of total calories obtained from fat and the proportion of total calories obtained from protein. Total calorie intake decreased in the MSI group but not the SSI group.
Obarzanek, 2001 ^218^ | Counseling intervention, same as DISC above. | Control: Usual care - parents informed child's blood cholesterol high and were given educational materials on heart-healthy eating as available to the public. | 663 randomized, 580 at last follow-up visit | 4 years (7 years total follow-up) | Results for years 1 and 3 are the same as presented in DISC study above Results for years 5 and 7 follow-up presented here. | | Good
| | | | | No difference between intervention group and control for LDL at 5 years (p=0.11) or final visit (yr 7) (p=0.25).
| | | | | No difference for TC at 5 or 7 years.
| | | | | No difference for HDL at 5 or 7 years.
| | | | | No differences in TG or LDL/HDL ratio.
| | | | | Intervention group had lower dietary total fat, saturated fat at all points (p<0.001) and lower cholesterol intake at year 5 (p<0.001).
Shannon, 1994 ^220^ | Parent-Child AutoTutorial Program (PCAT) included 10 talking book lessons and follow-up paper and pencil games for children with a manual for parents. Counseling treatment: 45–60 minute session with parent, child and registered dietitian, along with take home print materials for both. Dietitian available for phone to answer questions during 3 month period. | At-risk control group. | Ages 4–10 with LDL 107–164 for boys and 112–164 for girls (mg/dL) | 3 month follow-up | Mean LDL-C decline of PCAT (10.1mg/dL) was greater than in at-risk control (4.1 mg/dL) (p<.05). This represents an 8% decline in the PCAT group. | | Good
| | | | | Dietary knowledge scores: increased 3× more in PCAT vs. counseling or at-risk control (p<.001).
| | | | | Lipid intake: Mean grams of total and saturated fat decreased in PCAT/counseling group and increased slightly in at-risk control (p<.05).
Stallings, 1993 ^77^ | Parent-Child AutoTutorial Program (PCAT) 10 sessions total, 1 per week completed in home by child and parents | Usual Care: 1 hour session with registered dietician using AHA guide | 44 children ages 4–10 with LDL between 90–99th percentile. | 6 months | No between group differences at either 3 or 6 months for LDL. No results reported for TC, HDL or TG. | LDL decreased ~10% within both groups at both 3 and 6 months, (p<0.01). | Poor
| | | | | No differences between groups in knowledge, caloric intake, fat intake. Cholesterol intake was lower in PCAT group vs. control at 6 mo. (p<0.05) | Both groups had increases in knowledge at 3 and 6 months compared to baseline (p< 0.001).
| | | | | | No difference in caloric intake within groups.
| | | | | | Total fat intake decreased in both groups; no change in saturated fat intake; both groups decreased cholesterol intake.
Williams, 1995 ^229^ | Fiber cereal contained 3.2 g soluble fiber per serving. Dose=1 box of cereal per day for 3 weeks, then 2 boxes/day. Children ages 2–5 consumed only 1 box/day throughout study. | Placebo cereal with 0.5/g of fiber, 1 box/day × 3 weeks then 2 boxes per day; children ages 2–5 consumed 1 box per day. | 58 with TC>170 mg/dL and LDL>110mg/dL. | 12 weeks | TC decreased for fiber vs. Step 1(p<0.05), LDL decreased for fiber vs. Step 1 (p<0.01), no difference in HDL or TG between groups. | After 12 weeks: | Poor
| | | | | TC/HDL and LDL/HDL ratios improved (p<0.001). | Both groups had significant within-group decreases in TC, but decrease for fiber was significantly greater. TC decrease p<0.01 within Step I, p<0.001 within fiber group.
| | | | | | No change in HDL within groups
| | | | | | Fiber group had decrease in LDL (p<0.01), No change within step I group.
| | | | | | TG decreased for fiber group, with no change within step 1 group.

Abbreviations

AHA=American Heart Association, Apo A=Apolipoprotein A, Apo B=Apolipoprotein B, HDL=High-density lipoprotein, LDL=Low-density lipoprotein, TC=Total cholesterol, TG=Triglycerides

Dietary supplements trials included two poor quality studies of psyllium ^223,^ ^229^ , and one poor quality study of oat bran. ^231^ Psyllium supplements decreased TC and LDL-C (5% and 9% greater decreases in fiber group over control using Step I diet) in the one trial, ^229^ but had no effect in the other, ^223^ The trial of oat bran showed no significant changes in lipids. ^231^

Exercise treatment. Six studies, three fair quality ^225,^ ^232,^ ^233^ and the three poor quality ^226,^ ^228,^ ^230^ meeting inclusion criteria evaluated exercise in normal or obese children with elevated lipids (Table 11). The poor studies were rated poor because of differential or low completion rates (51–52%), small numbers of participants (≤20) resulting in low generalizability, among other problems (lack of blinding, lack of intention to treat).

Table 11 Randomized Controlled Trials of Exercise Trials for Children and Adolescents Without Identified Familial Hypercholesterolemia or Other Monogenic Dyslipidemia

Author, year | N | Duration of Trial | Intervention(s) | Control | Results | | Quality Rating
| | | | | Between Group Comparisons | Within Group Comparisons
Obese Children and Adolescents
Ferguson, 1999 ^225^ | 81 obese children mean age 9.5 | 4 months each period | Exercise program offered 5 days/week, 40 min per day; children were paid $1/session and given prizes for maintaining a HR>150 bpm. After school transportation was provided. | No exercise training program | Prior to cross-over, no p-values reported: | For change over 8 months (post-crossover), group × time interaction was significant for triglycerides only (p=0.02) Results also given for combined groups at the end of their intervention periods. | Fair
| | | | | TC decreased 6% for intervention group and 7% for control.
| | | | | HDL increased 4% for intervention vs 0% for control.
| | | | | LDL decreased 6% for intervention group vs 12% for control.
| | | | | TG decreased 17% for intervention vs an increase of 12% for control.
Kang, 2002 ^226^ | 80 obese children ages 13–16 | 8 months | Physical training (PT) offered 5 days/week for 8 months except when assigned to lifestyle education (LSE). | Lifestyle education alone. | Comparison of pre-post changes in mmol/L (least-square mean+SEM): | | Poor
| | | Physical training = individual exercise prescription, 1045 kJ/session (250kcal), mean prescribed HR of 55–60% or 75–80% of peak | | No significant change in TC or HDL compared to control.
| | | | | TG decreased for LSE+PT group as compared to control (p=0.003).
Healthy Children and Adolescents
Boreham, 2000 ^230^ | 25 sedentary but healthy female students ages 18–22 | 7 weeks | 7 week stair climbing program, progressing to 6 ascents/day on a public access staircase Mon–Fri (199 steps with a total vertical displacement of 32.8 meters). | No change in activity | Stair climbers had significant improvements compared to control in HDL (p<0.01) but not for TC. However, pre-intervention difference in HDL between stair climbing and control group was significant (p<0.05). | Pre-post results for stair climbers only in mmol/L, mean+SEM after 7 weeks: | Poor
| | | | | | TC decreased (p<0.05).
| | | | | | HDL increased (p<0.05). Controls had no signficant changes in lipid levels.
Linder, 1982 ^232^ | 50 healthy boy scouts ages 11–17 | 8 weeks | Physical conditioning program (PA) designed to increase aerobic capacity. | Usual summer activities. | Post-test physical working capacity increased in the PA group vs control group, p<0.05. | No significant differences in the change in TC, LDL, HDL, TG, VLDL levels from pre to post. | Fair
| | | | | No difference in TC, LDL, HDL, TG or VLDL between groups.
Savage, 1986 ^233^ | 663 prepubescent boys | 11 weeks | Walking/jogging/running 3 times/week for 11week (total distance of 1.6 km per session). Low intensity group had a training HR of 40% VO2 maximum. High intensity training group had a training HR of 75% VO2 max. | Control subjects were requested to maintain their current activity pattern throughout the study. | No significant differences between groups in the changes of HDL/total cholesterol ratio, TG, or LDL. Change in HDL-C values was significantly greater for the high intensity group (p<0.05) but not for the low intensity group as compared to control. | No significant changes in HDL/total cholesterol ratio, TG, or LDL. | Fair
Stergioulas, 1998 ^228^ | 58 sedentary high school boys ages 10–14 normal body weight and normal lipids | 2 months | Exercise: 2 month training program with four, 60 minute sessions per week. Sessions included warm-up, stretching, and aerobic exercise at 75% of physical work capacity. | No specific training program. Both groups advised not to change dietary habits or physical activity. | No significant differences between groups. | Physical work capacity of exercise group increased at the end of treatment (p<0.001). No change seen in control group. | Poor
| | | | | | HDL increased for intervention group at end of the 2nd treatment month (p<0.005) and at the end of the detraining period (p<0.01). No change seen in control group.

Abbreviations HDL=High-density lipoprotein, HR=Heart rate, LDL=Low-density lipoprotein, SEM=Standard error of measure, TC=Total cholesterol, TG=Triglycerides, VLDL=Very low-density Lipoprotein

In these studies, lipid levels were lower than those typically used to define FH (LDL-C<160mg/dL and TC<240 mg/dL). Two trials comparing supervised, scheduled sessions of aerobic and fitness training to control groups who received no specific regimen showed improvements in HDL-C for the intervention group. ^230,^ ^233^ The others showed minimal or no change in lipids compared to control groups. ^225,^ ^226,^ ^228,^ ^232^

A meta-analysis of these six exercise trials in healthy and/or overweight children and adolescents without identified FH or monogenic dyslipidemia showed non-significant increases in TC, LDL-C and HDL-C (Figures 10–12). This result did not change with exclusion of the poor quality studies, or with exclusion of the study of college-age women (an outlier because of age). However, trials were problematic because baseline lipid levels were different between the treatment and control groups, ^225,^ ^230,^ ^233^ suggesting that randomization may have been flawed. In these studies, the magnitude of difference in the baseline difference between the two groups could be larger or as large as the difference between baseline and endpoint. ^225,^ ^230,^ ^233^ These trials generally had small sample sizes and may not have had enough power to detect a significant effect. Also, most trials only reported the mean lipid level and its associated variance (or S.D.) at baseline and endpoint for both treatment and control groups, and our method to calculate standard error of percent change may have yielded a conservative estimate because the correlation between baseline and endpoints is ignored in the calculation (see Appendix 6).

Figure 10. Meta-Analysis of Exercise Trials in Children: Total Cholesterol Reduction

Figure 11. Meta-Analysis of Exercise Trials in Children: LDL-C Reduction

Figure 12. Meta-Analysis of Exercise Trials in Children: HDL-C Increase

Combination Diet and Exercise Treatment. Three trials meeting inclusion criteria, two fair ^221,^ ^222^ and one poor, ^217^ evaluated combined regimens of diet and exercise in this population (Table 12). One study showed a 23% increase in HDL-C for the exercise, diet plus behavior change group compared with no significant changes for either the diet plus behavior change or the control groups. ^221^ One “Know Your Body” curriculum study encouraged adoption of regular exercise programs and an AHA prudent diet, ^239^ and found a small decrease in TC that became significant after adjustment for age, gender and race. ^222^ The third trial combined the diet alone and diet plus exercise groups for analysis and found a 4% decrease in TC in the intervention groups compared to a 2.2% increase in the waiting list control group (p=0.03), a 20% increase in HDL-C compared to 6.5% increase in the control group (p=0.007), and a 41% decrease in TG for the intervention group vs. an 8% decrease for the control group (p=0.01). ^217^

Table 12 Randomized Controlled Trials of Diet and Exercise for Children Without Identified Hypercholesterolemia or Other Monogenic Dyslipidemia

Author, year | N | Duration of Trial | Intervention(s) | Control | Results | | Quality Rating
| | | | | Between Group Comparisons | Within Group Comparisons
Becque, 1988 ^221^ | 36 over-weight children ages. | 20 weeks | 1 Diet and behavior change: met with dietician and behavior therapist once/week. ADA exchange program set to elicit the loss 1–2 lbs/week.; Behavioral treatment included record keeping stimulus control, changing topography of eating and reinforcing altered behavior.; 2 Exercise plus diet and behavior change: same as above, with exercise program 50 minutes 3 days/week. | No change in activity or diet | Post-treatment HDL level for exercise, diet and behavior change group was significantly better from the control and from the diet plus behavior change post-treatment groups (p<0.05). | Control group had no pre-post differences in HDL, TC or TG (n=14). | Fair
| 3 small groups. | | | | No other between group differences | Diet and behavior change group had no pre-post differences in TC, HDL or TG (n=11).
| | | | | | Exercise, diet and behavior change group increased HDL (P<0.05) but did not change TC or TG (n=11).
Epstein, 1989 ^217^ | 56 obese (>20% of ideal weight) children ages 8–12 | 6 months | Diets were set between 3800–5000/kJ/day and monitored by a nutritionist to maintain nutrient adequacy. | | Results for the two intervention groups (diet or diet+exercise instruction) were combined for total treatment group n=35 and control n=16. | | Poor
| | | Information on diet, exercise, stimulus control, reinforcement, modeling and contingency contracting was presented to parents and their children in eight weekly sessions followed by four monthly sessions. | | TC decreased for intervention vs. control (p=0.03).
| | | | | HDL increased for intervention vs. control, (p=0.007).
| | | | | TG decreased for intervention vs. control (p=0.01).
Walter, 1985 ^222^ | 1115 4th graders | 1 school year (2 hours/ week) | “Know Your Body” curriculum yearly from 4th–8th grade; taught in usual classroom by regular teacher 2 hours/week for entire school year. | Usual curriculum | Adjusting for age, gender, race and baseline risk factor level, TC difference between groups was significant (p=0.03). HDL and HDL/TC differences were not significant (p=0.18 and p=0.06 respectively). | At year 1: | Fair
| | | Teachers trained by research staff in 3 half-day teacher workshops on curriculum implementation. Adherence to teaching protocols monitored by classroom visits from research staff and attendance at training workshops. | | | TC decreased 0.4% in the intervention group vs. a 0.5% increase in control group.
| | | | | | HDL decreased 7% in intervention group vs 9% in control group.
| | | | | | TC/HDL ratio decreased 9% for intervention vs 6% in control group.

Abbreviations

ADA=American Dietetic Association, HDL=High-density lipoprotein, TC=Total cholesterol, TG=Triglycerides

## Key Question 9. What are the Adverse Effects of Drug, Diet, Exercise, and Combination Therapy in Children/adolescents?

### Summary

Statin drugs are associated with elevations in liver enzymes and creatinine kinase (CK), and bile-acid binding resins are associated with non-serious gastrointestinal side effects and subclinical decreases in serum vitamins and minerals. There are reports of growth failure in children and adolescents on low-fat diets, particularly those who were placed on low-fat diets without formal nutritional assessment and advice. Most studies of children over two years old on low-fat diets reported normal growth and development. Studies were variable in the quality of adverse effect assessment and reporting, and too short to determine long-term effects.

### Evidence

Tables 13–17 and Evidence Table 5 provide details about adverse effects reported in studies of drug, diet, exercise, and combination therapies in children with elevated lipid levels. Data on safety of longer-term and more widespread use of statin drugs in adults are available in the recent Drug Class Review on HMG-Co Reductase Inhibitors, a systematic review of adverse effects of statins conducted by the Oregon EPC and updated in June 2005. ^50^

Table 13 Adverse Events Reported in Studies of Statins

Author, year, title | Study Design | N | Duration | Age (years) | Adverse Effects of Treatment | Laboratory Values
Atorvastatin
McCrindle, 2003 ^76^ | RCT | 187 | 26 weeks | 10–17, mean 14.1 | No significant adverse effects; No effect on sexual development. | Increased AST in 1%; Increased ALT in 1%. None withdrew or stopped med as a result of increased transaminases.
Lovastatin
Clauss, 2005 ^38^ | RCT | 54 girls | 24 weeks | 10–17 | None observed; no detectable effect on menstrual cycle length. | NR
Lambert, 1996 ^72^ | RCT | 69 boys | 8 weeks | <18, mean 12.7 | None observed. | Asymptomatic elevations in CK in 3 subjects.
Stein, 1999 ^78^ | RCT | 132 | 48 weeks | mean 13 | No effect on growth; No difference between drug and placebo in testicular volume, Tanner staging, testosterone, or LH level. | DHEAS increased by 18%. Tocopheral decreased. ALT increased in both drug and placebo; no differences between groups at week 48. No consistent changes in AST or CK. Transient CK elevations in response to exercise.
| | | | | | Mean CD3 lymphocyte count decreased from baseline of 2.72 + 0.91 nX10^9^ to 6-months of 2.34 + 0.81 nX10^9^ (p=0.003). Mean CD4 lymphocyte count decreased from baseline of 1.47 + 0.57 nX10^9^ to 6-months of 1.26 + 0.50 nX10^9^ (p=0.010). Mean CD8 lymphocyte count decreased from baseline of 0.89 + 0.34 to 6-months of 0.75 + 0.26 nX10^9^.
Pravastatin
Wiegman, 2004 ^37^ | RCT | 214 | 2 years | 8–18, mean 13 | No impact on growth, endocrine function parameters, Tanner staging scores, onset of menses or testicular volume. | No effects on muscle or liver enzyme levels.
Hedman, 2003 ^240^ | Open-label | 20 | 8 weeks | 4–15 | Abdominal pain (1), loose stools (1), headache (4), sleep disturbance (2), muscle tenderness or pain at rest (1), muscle tenderness or pain associated with physical training (1). | No effects on serum ALT, CK, or creatinine.
Knipscheer, 1996 ^71^ | RCT | 72 | 12 weeks | mean 12 | Rash, nose bleeding, headache, nausea/vomiting, abdominal pain. | CK abnormal in 8 of placebo, 6 of 5 mg/day, 11 of 10 mg/day and 8 of 20 mg/day groups. Cortisol abnormal in 2 of placebo, 2 of 5 milligrams per day, 5 of 10 milligrams per day, 3 of 20 milligrams per day groups.
Simvastatin
Couture, 1998 ^66^ | RCT | 63 | 6 weeks | 8–17, mean 12.6 | None observed. | NR
De Jongh, 2002 ^68^ | RCT | 69 | 28 weeks | 9–18, mean 14.6 | None observed. | No significant differences between simvastatin and placebo FH groups on ALT, AST, and CK.
De Jongh, 2002 ^69^ | RCT | 173 | 48 weeks | 10–17 | Abdominal pain (3), chest pain (1), flatulence (1), myalgia (2), headache (4), sleep disorder (1), weight gain (1), pruritus (1). | Increased ALT (3), AST (3), and CK (1).
Dirisamer, 2003 ^241^ | Open-label | 20 | 18 months | 10–17, mean 13 | Transient headache (2). Myalgia (1) for 2 weeks. Transient gastrointestinal complaints (2). | Slightly higher values of CK (2); Transiently elevated ALAT (GPT) and GCT (1).
Ducobu, 1992 ^243^ | Open-label | 32 | 24–36 months | <17 | Children for whom height (n=12) and weight (n=16) were available remained in the growth percentages they had been in at baseline. | Slight transaminase increase (n=1) and slight CK increase (n=2) were transient. No significant changes detected overall.
Stefanutti, 1999 ^244^ | Non-RCT | 16 | 12 months | 7–12, mean 8.75 | No adverse effects were observed with diet alone or with diet plus simvastatin. Patients showed good compliance with the treatment. | NR
Various or unspecified statins
Sinzinger, 2004 ^242^ | Descriptive | 22 professional athletes | 8 years | 15–27, mean 24.1 | Muscle pain reported in 84% of periods of statin therapy. Mean time of onset of muscle pain was 8.3 days. | Elevated CK in 3 subjects. No increase in liver enzymes.
De Jongh, 2003 ^70^ | Cross-sectional | 69 | NR | 10–18, mean 15.3 | No differences between the children with FH and their healthy peers on health-related quality of life and anxiety. | Not assessed.

Abbreviations

ALAT=Alanine aminotransferase, ALT=Alanine transaminase, AST=Aspartate aminotransferase, CK=Creatine kinase, DHEAS=Dehydroepiandrosterones, GCT=Glucose challenge test, GPT=Glutamic-pyruvic transaminase, FH=Familial hyperlipidemia, LH=Luteinizing hormone, NR=Not reported, RCT=Randomized controlled trial

Table 17 Adverse Events Reported in Studies of Dietary Supplements

Author, year, title | Dietary Supplement | Study Design | N | Duration | Age (years) | Adverse Effects of Treatment | Laboratory Values | Compliance/Tolerance
Amundsen, 2002 ^41^ (some data from Amundsen 2004) | Plant sterol ester spread 18.2 g/day of spread corresponding to 1.6 g/day of sterol esters. | RCT | 38 | 8 weeks | mean 10.5 | None observed. | ALT increased 16.8% (p = 0.04). After adjustment for lipid changes, lycopene was 8.1% lower (p=0.015) in treatment than in control group. lipid-adjusted serum retinol levels were 15.6% (p<0.001) higher in treatment than control groups. Lipid-adjusted lathosterol levels increased by 96% ; sitosterol increased by 48% | Children consumed 18 g/day of spread.
| | | | | | | | 1 subject withdrew because the amount of spread was too large.
Amundsen, 2004 ^287^ | Plant sterol ester spread (20 g of spread per day, corresponding to 1.76 g/day of plant sterol), some children took fish oil supplements or vitamins | Open-label trial, following RCT above | 37 | 26 weeks | mean 9.6 | NR | Lipid-adjusted lathosterol levels were stable; sitosterol levels were 77% higher compared to control period of RCT. | Children consumed slightly less spread (14 g/day vs 18 g/day during trial).
| | | | | | | Lipid-adjusted retinol levels were 11% higher at the end of the open label period as compared to control. No changes in lycopene or lutein.
| | | | | | | Lipid-adjusted serum a-carotene increased in the open label period following a decrease in the trial period.
Becker, 1993 ^288^ | Diet plus sitosterol pastils, then diet plus sitostanol | Open-label trial | 9 | 10 months: | mean 11.9 | Growth was normal. | Diet phase: ALT decreased. | All 9 subjects completed the study; good compliance with all treatments.
| | | | 3 sitosterol | | No abnormalities in liver and gallbladder. | Sitosterol: alk phos and carotene decreased. Sitostanol: ALP and carotene returned to initial values; transferrin increased slightly and serum bile acid levels decreased, but were within normal range. No changes in hemoglobin, leukocyte count, platelet count, calcium, phosphate, lipase, iron, creatinine, and creatinine kinase.
| | | | 7 sitostanol | | No changes in stool pattern.
Clarke, 1990 ^289^ | Fish oil 5 g/day | Observational | 11 | 6 months | 11–21 | 8 of 11 subjects had episodes of epistaxis that caused 2 to withdraw. One subject had asymptomatic occult blood in the stool on one occasion; the bleeding time was normal. | No evidence of liver dysfunction. All prothrombin and partial thromboplastin times and platelet counts were normal. | 2 (18.2%) of 11 subjects withdrew due to epistaxis.
Dennison, 1993 ^223^ | Psyillium fiber 6 g/day | RCT | 25 | 4–5 weeks | mean 11.1 | No changes in sub scapular or triceps skin-fold thicknesses. Height and weight growth were normal. | None of vitamin or mineral levels tested were decreased. | Compliance was 82% for both cereals.
Glassman, 1990 ^290^ | Psyillium fiber 5 g/day | Descriptive | 36 | 8.1 months | 9–17, mean 9.7 | No abdominal distention or cramping, constipation, diarrhea, or excessive flatus production. | No changes in serum zinc, copper, or hemoglobin concentrations; hematocrit; mean corpuscular volume; or prothrombin and partial thromboplastin times. | All patients tolerated both regimens well.
Gulesserian, 2002 ^291^ | Rapeseed oil substitution for all fats and food preparation | Descriptive | 17 | 5 months | 4–19, median 12.7 | NR | NR | The diet was well accepted; no patient withdrew due to dislike of the oil.
Gylling, 1995 ^39^ | Rapeseed oil-rich margarine substitution of fats (24 g/day) with sitostanol (3 g/day) | RCT | 14 HeFH, 1 HoFH | 6 weeks | 2–15, mean 9.1 | NR | NR | Reported good compliance; well tolerated.
| | | | | | | | Children noted no difference in taste between the two margarines.
Laurin, 1991 ^294^ | Soy-protein beverage | RCT | 10 | 4 weeks | mean 7.9 | Growth and development were normal. | NR | Reported good control over mean dietary intake; similar percentages of protein energy were consumed as a dairy source in the soy-protein and cow-milk diet groups.
McCrindle, 1998 ^235^ | Garlic extract | RCT | 30 | 8 weeks | 8–18, mean 14 | The most common effects were headache and upset stomach, and were similar between garlic and placebo groups. | Serum albumin level (+2.0 g/L, p=0.002) and hemoglobin (+5.2 g/L, p=0.02) with garlic. | 1 patient was unable to swallow the capsules and withdrew.
| | | | | | 1 patient on garlic had unpleasant body odor, but had been working concomitantly on a garlic farm during the study. | | Compliance was similar between garlic and placebo groups. 86% vs 93% (p=0.34).
Mietus-Snyder, 1998 ^292^ | Vitamins E (400 IU) and C (500 mg) twice daily | Non-randomized controlled trial | 11 | 6 weeks | 6–21, mean 12.5 | No adverse effects of antioxidant vitamin therapy reported. | NR | All subjects tolerated the study well.
Sanchez-Bayle, 2001 ^293^ | Fiber tablets (50% wheat bran, 50% pectin) 100–150 mg/kg/day | Observational | 53 | 3 months | 4–18, mean 7.3 | Two children reported abdominal discomfort and soft stools. | NR | Generally well tolerated; 2 withdrew due to abdominal discomfort
Schlierf, 1978 ^295^ | Sitosterol | RCT | 15 | 3 months | 8–20 | Not reported. | NR | Good compliance.
Zavoral, 1983 ^296^ | Locust bean gum (LBG) | Non-RCT cross-over trial | 11 | 8 weeks | 10–18 | Increased rectal gas for 1 to 2 weeks while on the LBG-containing products. | No change observed in the white blood cell counts, serum calcium, or SGOT determinations. | Children ate the prescribed amount of LBG food products.

Abbreviations

ALP=Alkaline phosphatse, ALT=Alanine transaminase, HeFH=Familial hyperlipidemia, HoFH=Familial homozygous hyperlidpidemia, NR=Not reported, RCT=Randomized controlled trial, SGOT=Serum glutamic-oxalocetic transaminase

#### Drug treatment

Information about adverse events was reported in 15 studies of statins (Table 13), ^37,^ ^38,^ ^66,^ ^68^ – ^72,^ ^76,^ ^78,^ ^240^ – ^244^ in 22 studies of bile-acid binding resins (Table 14) reported in 23 publications, ^74,^ ^75,^ ^80,^ ^81,^ ^245^ – ^263^ and in 9 studies of various other drugs or drug combinations (Table 15). ^54,^ ^73,^ ^82,^ ^264^ – ^269^ Studies used randomized controlled trial, open-label trial, non-comparative, retrospective, and other descriptive designs. Where possible, prevalence rates are reported for studies with more than 20 participants.

Table 14 Adverse Events Reported in Studies of Bile-acid Binding Resins

Author, year, title | N | Duration | Age (years) | Adverse Effects of Treatment | Laboratory Values
Cholestyramine
Curtis, 1991 ^245^ | 1 | 2 years | 7 | Loss of dental enamel noted. This was presumed due to low pH (2.4) of cholestyramine mixed with Kool-Aid (and swished by child in his mouth for 15 min before swallowing) | Serum calcium, phosphorus, folate, B12 were normal
Farah, 1977 ^246^ | 20 | 16 days | 4–23, mean 15 | Febrile gastroenteritis in 1 patient after 7 days treatment resulting in discontinuation of therapy. | Serum folate decreased significantly in females. 7/11 females had folate measured after treatment and results only reported in aggregate by gender. SGOT increased in 2 patients (32 and 41 IU/dL), and persisted 6 months. Transient LDH increases (>60 IU/dL) in 2. No fat-soluble vitamin malabsorption.
Farah, 1977 ^247^
Glueck, 1973 ^263^ | 20 on diet +BABR | 6 months with additional 12–18 months follow-up for growth | 7–21 | 10 of 12 routinely took the suggested dose of cholestyramine. | No consistent changes in any of the laboratory safety tests (CBC, liver function tests, BUN, calcium, phosphorous, total protein, electrolytes and carbon dioxide). No evidence for hypercholoremic acidosis at any time.
| | | | Weight gain and growth progressed during the 12 and 18 month follow-up period along normal growth percentile
Glueck, 1974 ^262^ | 30 on diet + BABR | average follow-up of 6 months | 5–21 | NR | Plasma vitamins A and E remained within the normal range and paralleled at higher levels the 25th to 75th percentile distirbution for vitamin A and E in normal children.
Glueck, 1977 ^260^ | 16 (same children as Glueck 1973 above) | 16 children followed for 18 months; 12 for 24 months; 7 for 30 –36 months | 9–17 | 11 of 16 had good adherence. 5 children dropped out after 2 years because of poor palatability of the drug. | CBC, liver function tests, vitamin A and E, calcium, phsophorus, blood urea nitrogen, fasting blood sugar levels did not vary signficantly over time when compared to baseline levels on diet only.
| | | | 1 child had persistent constipation. None had nausea. 5 complained that resin was gritty, had poor palatability. 1 complained of chronic fatigue
Glueck, 1986 ^261^ | 33 | 4.3 years | mean 10.3 | Height and weight percentiles at completion were unchanged from baseline. No abnormal growth patterns noted. Sexual maturation was normal. None had unusual infections or extra school sick days. None of the girls had ammenorrhea; though 1 competitive cross-country runner had persistently irregular periods. No depression, suicide attempts or traumatic deaths. | NR
| | | | 4 children exhibited transient refusal to follow diets and/or take bile acid-binding resins.
Koletzko, 1992 ^251^ | 35 on diet; 14 on diet + BABR | Diet: mean 17.5 mos. Diet+BABR: mean 27.9 months | 2–17, mean 7.9 | No serious side effects were noted with both forms of treatment (diet/ diet + BABR). Normal growth. Mild gastrointestinal symptoms occurred in “very few” patients. | NR
Liacouras, 1993 ^252^ | 87 | Up to 62 months | mean 10.6 | 12 nausea, 2 abdominal bloating, 1 severe constipation. 73% complained of poor palatability | No elevated prothrombin times.
McCrindle, 1997 ^74^ | 40 | 28 weeks | 10–18 | Minor gastrointestinal complaints were frequent but did not result in any drop-out | NR
Tonstad, 1996 ^81^ | 96 | 1 year | 6–11 mean 8 | Growth and bone age were normal. One case of intestinal obstruction caused by adhesions in 1 patient. Unpalatability, headaches, and vomiting were reasons for withdrawals. | Folate deficiency occurred in most subjects with cholestyramine, and vitamin D levels decreased significantly for those not taking a multi-vitamin. No other significant differences in nutrient levels. Hemoglobin and liver enzymes were unchanged.
Tonstad, 1998 ^255^ | 96 | 1 year | 6–11 mean 8 | 22/36 treatment and 26/36 placebo participants completed the trials thought secondary to unpalatability of drug. | During cholestyramine treatment, plasma total homocysteine increased in subjects with the C677T mutation in one or both alleles but not in subjects with the CC genotype.
West, 1973 ^256^ | 19 | Up to 20 months | | Some had impaired fat absorption without diarrhea. Growth was normal. None developed anemia. | Serum folate decreased in all patients. Hemoglobin, prothrombin time, serum calcium, alkaline phosphates, and serum vitamin A concentrations were unchanged.
West, 1975 ^257^ | 18 | 1 to 2.5 years | 1–14 | No child developed diarrhea, and growth was normal. | Folate deficiency and decreased red cell folate. Prothrombin time remained normal in all patients. There was a significant decrease in mean serum levels of vitamins A and E and inorganic phosphorus. Levels of serum iron, vitamin B12, plasma calcium, and protein did not change significantly.
West, 1975 ^258^ | 45 | 2–8 years | 1–16 | Adherence was poor due to unpalatability of cholestyramine. | Folate deficiency, steatorrhoea, and reduction in serum levels of vitamins A and E and of inorganic phosphorus although not to abnormally low values.
West, 1980 ^259^ | 35 | 1–8 years | 1–17, mean 8.4 | Almost all children expressed some dislike of cholestyramine, and a few complained of transient gastric fullness. No patient had persistent constipation, loss of appetite or diarrhea. Nausea, dizziness and malaise in a female aged 18. One boy died of intercurrent infection 10 months after starting meds, not stated whether related to treatment. | NR
Colestipol
Groot, 1983 ^248^ | 33 | 16 weeks | NR | 5 withdrew due to unpalatability. | NR
Hansen, 1992 ^249^ | 30 | 8.5 years (diet); 5.5 years (diet followed by diet + BABR) | 1–17 | One child's height/age decreased below -2 SD. Growth was normal in other children | NR
Harvengt, 1976 ^250^ | 3 | Up to 36 months | 6, 11, 18 | No hepatic dysfunction, renal function, or hematologic side effects observed. Mild gastrointestinal complaints (flatulence, constipation) during first 3 months, but disappeared despite continued treatment. No steatorrhea. | Low iron without anemia in one. Serum uric acid level increased during treatment but did not reach abnormal values. Serum vitamin B12 and folic acid content were not impaired after 2 and 3 years on colestipol. Prothrombin time values were not abnormally prolonged.
McCrindle, 2002 ^75^ | 40 | 36 weeks | 9–18, median 14 | 18% reported constipation, 21% had stomachache, 11% had headache, 6% had muscle aches. Compliance was 57–66% overall and was similar among treatment groups and dose groups. | NR
Schwarz, 1980 ^253^ | 23 | Up to 24 months | 5–17, mean 12 | 6 subjects complained of poor palatability. 1 patient developed Reynauld's phenomenon during therapy but continued treatment without recurrence of symptoms. | Serum vitamins A and E decreased significantly after 18–24 months of colestipol. No changes in 25-hydroxycholecalciferol, folic acid or prothrombin time.
Tonstad, 1996 ^80^ | 66 | 52 weeks | mean 13.2 | 8 had gastro-intestinal side effects, including constipation, dyspepsia, flatulence, nausea, decreased appetite, abdominal pain. Growth was normal. | Low-dose colestipol (10 g/day) reduced concentrations of serum folate after 8 weeks. Serum vitamin E and carotenoids decreased proportionally with decreases in cholesterol. Vitamin D did not change significantly, but decreased more in subjects who were more compliant after 1 year.
Tonstad, 1996 ^254^ | 27 | 6 months for colestipol; mean 6 years for diet | 10–16 | Growth was normal. Two had difficulty swallowing the tablets; one had difficulty with flatulence; one had abdominal discomfort. | NR

Abbrevations

BABR=Bile acid binding resin, BUN=Blood urea nitrogen, CBC=Complete blood count, LDH=Lactate dehydrogenase, NR=Not reported, SGOT=Serum glutamic-oxalocetic transaminase

Table 15 Adverse Events Reported in Studies of Other Drugs and Combinations

Author, year, title | Drug | Study Design | N | Duration | Age (years) | Adverse Effects of Treatment | Laboratory Values | Compliance/ Tolerance
Baker, 1982 ^54^ | Probucol | Open-label trial | 7 | 15–21 months | 6–21 | Nausea in one patient; Growth and development were normal. | No significant changes in endocrine, hepatic, or hematological investigations. Levels of total T1 and T4, and of free T1 and T4 did not change. | Well tolerated
Becker, 1992 ^264^ | Sitosterol and bezafibrate, in sequence and in combination | Open-label trial | 7 | 3 months sitosterol; 3 months bezafibrate; 24 months sitosterol + bezafibrate | mean 8.4 | Two had decreased appetite for the first 2 weeks on sitosterol. Ultrasounds of gallbladder found no abnormalities. | Sitosterol: slight, significant decrease in hemoglobin (-5%) and ALP (-19%). | Children and parents reported a high degree of acceptance and compliance during all treatments.
| | | | | | | Bezafibrate: ALP remained lower; iron increased by 26%.
| | | | | | | Combination: transferrin increased 20% and reached abnormal levels in 2; all other lab values normal.
Brun, 1980 ^265^ | Dextrothyroxine (D-T4) | Descriptive | 6 | 12 weeks | 7–12 | NR | With D-T4 treatment, the secretion of both TSH and T3 in response to TRH was abolished. An increase in the basal level of T3 was observed after treatment with D-T4. The high circulating levels of D-T4 and possibly of D-T3 after chronic administration of D-T4 may be responsible for the saturation of pituitary nuclear T3 receptors, resulting in the suppression of the TRH-induced TSH response. | NR
Colletti, 1993 ^266^ | Niacin | Retrospective | 21 | 1–19 months, average 8.1 | 4–14 | 18 of 21 patients reported some adverse effect: flushing 71%, itching 19%, abdominal pain 14%, nausea 14%, headache 14%, constipation 5%. One subject developed febrile illness with serum aminotransferase >400 IU/L two months after starting niacin. Niacin at 1000 mg/day-sustained release was considered a possible cause of hepatitis. | Reversible serum aminotransferase elevations (dose related) in 6 patients: 4 with crystalline and 2 with sustained release form of niacin. | 18 of 21 patients reported some adverse effect. Drug was discontinued in 1 subject due to poor compliance.
Malloy, 1978 ^73^ | P-amnosalicylic acid | RCT | 20 | 6 months | 5–21, mean 12 | No indicators of drug toxicity reported, other than mild gastric irritation that remitted with oral antacid treatment. | Normal SGOT, SGPT, ALP, bilirubin, and glucose levels in fasting serum; normal TSH and thyroxine. | Compliance was >50% for 11 subjects, <50% for 9 subjects.
| | | | | | | Triiodothyronine levels were slightly below normal for 2 in active drug and 1 on placebo.
McDuffie, 2002 ^267^ | Orlistat | Observational | 20 | 3 months | mean 14.6 | Effects were generally mild, limited to gastrointestinal effects related to increased fat excretion, and resolved within the first 6 weeks of treatment. | A small but significant drop in 25-hydroxy vitamin D levels was seen at 1 month. 3 subjects required additional vitamin D supplementation despite the prescription of a daily multivitamin containing vitamin D. TSH, free thyroxine, glycosylated hemoglobin, calcium, phosphorous, magnesium, zinc, measures of iron stores did not change significantly. | Subjects who completed treatment (85%) reported taking 80% of prescribed medication.
| | | | | | | | Only one subject (5%) cited intolerance of adverse effects as reason for withdrawal.
Stein, 1989 ^268^ | Diet + drug or combined drugs: BABR; BABR + niacin; lovastatin or simvastatin | Cross-sectional | 30 | 1–9 years | 1–20, mean 5.5 | No adverse clinical or biochemical side effects were noted on the HMG CoA reductase inhibitor. | Resin + niacin together produced elevated AST and ALT and clinical symptoms of hepatotoxicity in one subject. Niacin in this subject was associated with a significant rise in liver enzymes, suppression of albumin, and clinical symptoms of hepatotoxicity. | NR
Steinmetz, 1981 ^269^ | Fenofibrate | Descriptive | 17 | 18 months | 4–19 | NR | 4 of 17 subjects had increased ALT (at least 100%) and AST (at least 80%). Uric acid decreased significantly (mean change -20%). Bilirubin decreased significantly (mean change -19%). Inorganic phosphates decreased slightly but significantly. Albumin was unchanged. ALP decreased by mean 15%. GGT decreased slightly (by 1.5 U/l). ALT increased by 9 U/l. AST increased by 11 U/l. | NR
Wheeler, 1985 ^82^ | Bezafibrate | RCT | 14 | 3 months | 4–15, mean 10.9 | Growth was satisfactory throughout trial. No other reports of adverse effects | One child had high alk phos after 3 months of bezafibrate. Another child had slight transient rise in ALT during first 2 months on bezafibrate but values were normal by end of 3rd month. | All subjects declared preference for this drug over cholestyramine used previously.

Abbreviations

ALP=Alkaline phosphate, ALT=Alanine transaminase, AST=Aspartate aminotransferase, BABR=Bile acid binding resin, NR=Not reported, SGOT=Serum glutamic-oxalocetic transaminase, SGPT=Serum glutamic-pyruvic transaminase, TRH=Thyroid releasing hormone, TSH=Thyroid stimulating hormone

Statins were associated with increased ALT and AST in three studies (0–3% of participants in RCTs), ^69,^ ^76,^ ^241^ while six other studies found no changes in liver enzymes overall. ^37,^ ^68,^ ^78,^ ^240,^ ^242,^ ^243^ CK levels were elevated in five studies (range 0.5–4% reporting a significant change in CK, with one study reporting 45% having any abnormal CK test, but none statistically significant), ^69,^ ^71,^ ^72,^ ^241^ – ^243^ were normal in four studies, ^37,^ ^68,^ ^78,^ ^240^ and subjects reported myalgia in four studies. ^69,^ ^240^ – ^242^ Normal sexual development was reported in four studies. ^37,^ ^38,^ ^76,^ ^78^ No studies observed an adverse effect of statins on sexual development or endocrine function, although one study observed an 18% increase in dehydroepiandrosterone sulfate (DHEA) levels with lovastatin compared with a 5% increase with placebo. ^78^ Other adverse effects of statins include gastrointestinal complaints in four studies, ^69,^ ^71,^ ^240,^ ^241^ rash/pruritus in two studies, ^69,^ ^71^ and headache in three studies. ^69,^ ^71,^ ^241^ A study of psychological effects found no adverse effects associated with statin therapy. ^70^ Statins have known drug interactions with erythromycin which can precipitate rhabdomyolosis. ^50,^ ^76^

Bile-acid binding resins were associated with gastrointestinal complaints (8–26%), such as flatulence and constipation, in 11 studies, ^74,^ ^75,^ ^80,^ ^81,^ ^247,^ ^250,^ ^252,^ ^254,^ ^256,^ ^259,^ ^260^ and their unpalatability (up to 50%) was noted in seven studies. ^248,^ ^252,^ ^253,^ ^255,^ ^258^ – ^260^ Reduced serum folate occurred with colestipol in one study ^80^ and with cholestyramine in five studies, ^81,^ ^247,^ ^256^ – ^258^ one of which reported reduced folate occurring only in the females. ^247^ Other studies reported no reduction of serum folate after 2 to 3 years of treatment with colestipol. ^250,^ ^253^ One study of cholestyramine ^257^ and one study of colestipol ^253^ reported a significant decrease in serum levels of vitamins A and E and inorganic phosphorus, but others demonstrated normal vitamin A and E levels over time. ^260,^ ^262^ One study of cholestyramine reported transient increases in LDH, and abnormalities in SGOT that persisted for 6 month, ^247^ but others showed normal liver function tests. ^260,^ ^262^ One study reported a child whose height for age dropped below -2 S.D. while on colestipol (1 S.D. = 2.4 cm). ^249^ Growth was reported normal in seven studies, ^80,^ ^81,^ ^250,^ ^251,^ ^256,^ ^257,^ ^261^ including sexual maturation over 4.3 years of treatment. ^261^ There was one case report of extensive loss of dental enamel in a 7-year-old boy after two years of cholestyramine use. This is thought to have resulted from mixing cholestyramine in Kool-Aid and the child holding the mixture in the mouth for 10 to 15 minutes before swallowing. ^245^ Serum calcium, phosphorus folate, and vitamin B12 values, and results of a radioactive bone mineral analysis were normal.

Other drugs studied were fenofibrate, bezafibrate, niacin, dextrothyroxine (D-T4), orlistat, P-aminosalicylic acid, and probucol. These studies enrolled small numbers (7–30, mean 15.8) of subjects. A study of fenofibrate reported significant decreases in total alkaline phosphatase, uric acid, inorganic phosphates, and bilirubin, and increases in ALT and AST levels. ^269^ A study of bezafibrate observed high alkaline phosphatase in one child. ^82^ The combination of bezafibrate and sitosterol resulted in decreased alkaline phosphatase and increased transferrin levels (by 20%) in two subjects. ^264^

Two of two studies of niacin reported increased liver enzymes (6 of 21 children in one study), and multiple other symptoms (flushing, abdominal pain, nausea, headache). ^266,^ ^268^ One seven year-old girl developed an influenza-like febrile illness with serum aminotransferase levels >400 IU/L two days after starting niacin. Niacin was considered a possible cause and was discontinued. ^266^ In another study of niacin combined with a bile-acid binding resin, one participant developed clinical symptoms of hepatotoxicity. ^268^

P-aminosalicylic acid was associated with mild gastric irritation. ^73^ A study of probucol reported nausea in one of seven patients, but probucol was otherwise well-tolerated, and growth and development were normal after 15 to 21 months of treatment. ^54^ Orlistat was associated with a significant drop in 25-hydroxy-vitamin D levels after one month. ^267^ Three of 20 subjects enrolled in this study required additional vitamin D supplementation despite the prescription of a daily multivitamin containing vitamin D. In a study of the effects of D T4 on the pituitary-thyroid axis of hypercholesterolemic children, an increase in the basal level of T3 was observed after treatment with D-T4, and the expected stimulation of TSH and T3 secretion in response to TRH was absent. ^265^

#### Low-fat diet

Nineteen studies of dietary fat restriction reported effects on growth, nutrient intake, laboratory safety parameters, or other adverse effects (Table 16). ^218,^ ^219,^ ^227,^ ^270^ – ^285^

Table 16 Adverse Events Reported in Studies of Low Fat Diet

Author, year, title | Study Design | N | Duration | Age (years) | Growth | Adverse Effects of Treatment | Laboratory Values
Cetta, 1994 ^279^ | Retrospective | 63 | 2 years | 2–16, mean 7.8 | Normal height. Weight loss in 2 females: 1 with anorexia nervosa, 1 with a more restrictive vegetarian diet. | NR | NR
Copperman, 1995 ^270^ | Cross-sectional | 54 | NA | mean 10.8 | NR | NR | Normal intake of energy, minerals, or vitamins D and E.
DISC Collaborative Research Group, 1995 ^219^ | RCT | 663 | 3 years | mean 9.4 | Normal | NR | Intake was low for vitamin E and zinc.
Feoli-Fonseca, 1998 ^282^ | Retrospective | 16 | 23 years reviewed; mean follow-up 6.76 years | infants (<1 year) with familial chylomicronemia | Normal | 2 children had severe abdominal pain, and another had acute pancreatitis after using an oral contraceptive agent. | Abnormal values were observed for serum iron, alkaline phosphatase, and total calcium. All erythrocyte folate and albumin levels were within normal range.
Jacobson, 1998 ^280^ | Observational | 138 | 3 years | 2–15 | Normal | NR | NR
Kaistha, 2001 ^285^ | Cross-sectional | 80 | N/A | 9.9 | NR | NR | More children with hyperlipidemia than controls (p<0.05) consumed below 75% of the RDA/DRI for vitamin E and calories.
Kuehl, 1993 ^227^ | RCT | 295 | 33 weeks | mean 7 | Normal | NR | Iron intake maintained at over 87% and calcium intake at over 81% of the RDA throughout the study.
Lavigne, 1999 ^281^ | RCT | 663 | Mean follow-up 36.2 months | 8–10 | NR | No adverse effects of treatment in academic function, psychological symptoms, or family function. | NR
Lifshitz, 1989 ^278^ | Observational | 40 | Mean time since diagnosis: 20.1 months (with growth failure); 3.9 months (without growth failure) | mean 7.7 | 8 (20%) of 40 patients had growth failure. | NR | The 3 patients with nutritional dwarfing consumed <60% of required energy, <50% RDA of vitamins B6, D, folacin, zinc, iron, calcium, and magnesium, and <66% of RDA for vitamins A and B12, niacin, and phosphorus. Only vitamins E and C were adequately consumed.
| | | | | Three had nutritional dwarfing with no progression of puberty.
| | | | | The other 5 had a drop in body weight without linear growth alterations.
McKenzie, 1996 ^274^ | Prospective cohort | 300 | 3 months | 4–10 | NR | NR | 74% failed to consume two thirds of the RDA for vitamin D.
Moreno, 1998 ^275^ | Descriptive | 42 | 6 months | 7–15 | NR | NR | Lymphocyte T subset counts (CD3, CD4, and CD8) showed significant decreases after 6 months but were within normal ranges.
Obarzanek, 2001 ^218^ | RCT | 663 | 4 years | mean 9.5 | Normal height, BMI, and sexual maturation | NR | No abnormalities in serum ferritin, red blood cell folate, serum retinol and zinc.
Rose, 1976 ^277^ | Descriptive | 16 | 16 followed for 1 year; 9 for >1 year | 1 month to 20 years | Normal | None observed | NR
Sanchez-Bayle, 1994 ^276^ | Observational | 451 | 6–24 months | 2–18 | Normal | NR | NR
Sanchez-Bayle, 2003 ^283^ | Prospective | 144 | Mean 7.42 years | 2–13, mean 5.5 | Normal height. Increase in weight | NR | NR
Segall, 1970 ^272^ | Observational | 5 | 10 days | 6–15 | 1 child lost 1.4 kg, another child gained 1.2 kg | NR | In all subjects, serum triglyceride increased after 3–6 days on the high-carb diet. TG levels fell on resumption of a diet containing 45% carbohydrates.
Tershakovec, 1998 ^284^ | RCT | 261 | 12 months | 3.9–9.9 | Normal | None noted. | NR
Tonstad, 1996 ^271^ | Cross-sectional | 185 | N/A | 7–16 | Normal | Normal behavioral and emotional scores. | NR
Witschi, 1978 ^273^ | Observational | 91 | 3 week diet period | Adolescents | Normal | NR | NR

Abbreviations

BMI=Body mass index, DRI=Dietary reference intakes, NA=Not applicable, NR=Not reported, RCT=Randomized controlled trial, RDA=Recommended daily allowance, TG=Triglycerides

Twelve studies reported normal height growth, ^218,^ ^227,^ ^271^ – ^273,^ ^276,^ ^277,^ ^279,^ ^280,^ ^282^ – ^284^ although weight loss occurred among three children in two of these studies. ^272,^ ^279^ Weight loss in one subject was caused by anorexia nervosa, and in another by a parent-instituted vegetarian diet that was more restrictive than recommended. ^279^

Growth failure in one study occurred among 8 of 40 (20%) children with dyslipidemia, 3 (7.5%) of whom had nutritional dwarfing and no progression of puberty. ^278^ Those with growth failure were ages 7–13 at diagnosis. In this study, families received general advice to reduce dietary fat and cholesterol at the time of diagnosis, but the specific recommendations varied in each case and implementation by the families was unsupervised. The period of unmonitored dietary restriction ranged from 2 weeks to 4.5 years and those with nutritional dwarfing had longer periods of time between diagnosis and formal dietary assessment and counseling. ^278^ Total energy and zinc consumption were lower in those with growth failure. All three children with nutritional dwarfing had inadequate intake of multiple different vitamins and minerals. Other studies reported inadequate intake of vitamin D, ^274^ vitamin E, ^219,^ ^285^ , and zinc. ^219^ Failure to thrive has been demonstrated in children under age two eating fat-restricted diets. ^286^ Fat-restricted diets are not recommended for children under age two because fat and cholesterol are necessary for normal growth and development in children under age two. ^35^

A study of lymphocyte T subset counts found significant decreases in CD3, CD4, and CD8 after six months of dietary therapy. ^275^ The changes in CD3 and CD8 counts were significantly correlated with changes in triglyceride serum levels. In all cases, lymphocyte T subset counts remained within normal ranges. The other immune indexes (immunoglobulins G, A, M, and complements C3, C4, and Factor B) did not change significantly.

Two studies of the psychological effects of diet therapy reported no adverse effects in academic function, psychological symptoms, and family function, ^281^ or in behavioral and emotional assessment scores. ^271^

A retrospective study of familial chylomicronemia observed patients in whom dietary intervention since infancy had provided at most 10% of energy as long-chain triglycerides. ^282^ The study observed abnormal values for serum iron, alkaline phosphatase, and total calcium. Two children experienced severe abdominal pain, and an adolescent female developed acute pancreatitis after using an oral contraceptive agent.

#### Dietary supplements

Fourteen studies provided information about the adverse effects of various dietary supplements, including fiber, rapeseed oil, plant sterol or stanol esters, fish oil, soy-protein beverage, garlic extract, locust bean gum, and antioxidant vitamins (Table 17). ^39,^ ^41,^ ^223,^ ^235,^ ^287^ – ^296^

Two children (4% of the treatment group) reported abdominal discomfort using fiber tablets that contained 50% wheat bran and 50% pectin, administered at 100–150 mg/kg/day. ^223,^ ^290,^ ^293^ There were no adverse effects with psyllium fiber in two other studies. ^223,^ ^290^

Studies of rapeseed oil alone, ^291^ or in combination with sitostanol ^39^ did not report adverse effects, and both studies reported that the diets were well-tolerated with good compliance. A plant sterol ester spread that provided 1.6 g/day of sterol ester reported an increase in ALT of 16.8% of participants. ^41^ A longer study of plant sterol ester spread reported increased retinol levels, but no increase in transaminases. ^287^ Sitosterol and sitostanol given in succession decreased alkaline phosphatase. ^288^ In a study of fish oil (5 g/day), epistaxis occurred in eight of 11 subjects, thought to be secondary to decreased platelets that can occur with omega-3 fatty acids. Prothrombin and partial thromboplastin times and platelet counts were normal, and there was no evidence of liver dysfunction. ^289^ After adjustment for lipid changes, lycopene was 8.1% lower (p=0.015), and serum levels of retinol were 15.6% higher (p<0.001), compared with controls. Studies of antioxidant vitamin therapy, ^292^ substitution of a soy-protein beverage for cow's milk, ^294^ and garlic extract ^235^ showed no significant adverse effects. A study of locust bean gum food products reported increased rectal gas that resolved after 1 to 2 weeks, with no other adverse effects or abnormal lab values. ^296^

#### Exercise

A school-based program examined the effect of supervised exercise training on the lipid profiles of normal prepubertal children and reported 100% adherence and no adverse effects. ^297^ In another study, treadmill tests elicited an exaggerated blood pressure response in boys with dyslipidemia. ^298^ These subjects had significantly higher blood pressures after exercise compared with normal controls (systolic 182 vs. 160 mmHg, p<0.0003; diastolic 77 vs. 9 mmHg, p<0.03), and their systolic blood pressures remained significantly higher at the end of recovery (120 vs. 112 mmHg, p<0.005).

## Key Question 10. Does Improving Dyslipidemia in Childhood Reduce the Risk of Dyslipidemia in Adulthood?

No studies were identified that directly evaluated whether treatment of idiopathic dyslipidemia in childhood reduces the risk of dyslipidemia in adulthood. Indirect evidence includes: Tracking of lipid during childhood and adolescence (40–55% remain in the highest quintile); and data from young adults whose CHD risk 22–42 years later was associated with their baseline lipid levels. ^4^ Identification and treatment of previously undiagnosed secondary dyslipidemia (e.g. hypothyroidism) can improve lipids. Children with FH continue to fully express the phenotype in adulthood and the natural history of this disease is early CHD. Thus, in FH populations, long-term placebo controlled trials of drug therapy may be unethical.

## Key Question 11. What are the Cost Issues Involved in Screening for Dyslipidemia in Children/adolescents?

Seven studies addressed the cost of screening children and adolescents. These studies reported overall costs of screening but did not relate it to effectiveness of the screening test, or take a societal perspective on the analysis of cost. ^130,^ ^177,^ ^178,^ ^182,^ ^183,^ ^299,^ ^300^ The only cost-effectiveness study identified was based in England and used a simulated population ages 16–54. ^301^ This study determined that population screening of 16 year olds only was as cost-effective as family tracing. However, these results may not be applicable to the U.S. No cost-effectiveness studies addressed screening in children younger than 16.