# Acknowledgments

This systematic evidence review was funded by the Agency for Healthcare Research and Quality (AHRQ) for the U.S. Preventive Services Task Force (USPSTF), and the investigators acknowledge the contributions of Janelle Guirguis-Blake, MD, Task Order Officer and Medical Officer, AHRQ. Members of the USPSTF who served as leads for this project include Leon Gordis, MD, DrPH, Carol Loveland-Cherry, PhD, RN, FAAN, Albert Siu, MD, MSPH, and Barbara Yawn, MD, MSc, FAAFP. Investigators thank the following expert reviewers of this report for commenting on draft versions, Peter Belamarich, MD, Shifan Dai, MD, PhD, Steve Daniels, MD, PhD, Roger Illingworth, MD, Patrick McBride, MD, MPH, and Ellis Neufeld, MD, PhD. Investigators also thank Andrew Hamilton, MLS, MS for conducting the literature searches and Miranda Walker, BA for her extensive assistance with the report.