# Appendix 1. Quality Rating Criteria

## Randomized Controlled Trials (RCTs) and Cohort Studies

### Criteria

- Initial assembly of comparable groups: RCTs—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to follow-up or overall high loss to follow-up
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies, or intension-to-treat analysis for RCTs

### Definition of Ratings Based on Above Criteria

- Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (follow-up at least 80 percent); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention to confounders in analysis.
- Fair: Studies will be graded “fair” if any or all of the following problems occur, without the important limitations noted in the “poor” category below: Generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred in follow-up; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for.
- Poor: Studies will be graded “poor” if any of the following major limitations exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention.

## Case Control Studies

### Criteria

- Accurate ascertainment of cases
- Nonbiased selection of cases/controls with exclusion criteria applied equally to both
- Response rate
- Diagnostic testing procedures applied equally to each group
- Measurement of exposure accurate and applied equally to each group
- Appropriate attention to potential confounding variable

### Definition of Ratings Based on Above Criteria

- Good: Appropriate ascertainment of cases and nonbiased selection of case and control participants; exclusion criteria applied equally to cases and controls; response rate equal to or greater than 80 percent; diagnostic procedures and measurements accurate and applied equally to cases and controls; and appropriate attention to confounding variables.
- Fair: Recent, relevant, without major apparent selection or diagnostic work-up bias but with response rate less than 80 percent or attention to some but not all important confounding variables.
- Poor: Major selection or diagnostic work-up biases, response rates less than 50 percent, or inattention to confounding variables.

Quality ratings criteria for randomized controlled trials, cohort studies, and case-control studies based on methods developed by the USPSTF.^1^

## Systematic Reviews

### Criteria

- Were the search methods reported?
- Was the search comprehensive?
- Were the inclusion criteria reported?
- Was selection bias avoided?
- Were the validity criteria reported?
- Was validity assessed appropriately?
- Were the methods used to combine studies reported?
- Were the findings combined appropriately?
- Were the conclusions supported by the reported data?
- What was the overall scientific quality of the overview?

### Definition of Ratings Based on Above Criteria

- Good: Recent, comprehensive review that uses explicit criteria to identify and select studies for inclusion, uses appropriate methods to assess quality of primary studies appropriately, and uses appropriate methods for synthesizing or combining results
- Fair: Systematic methods for identifying studies but doesn't meet one or more of the criteria listed above.
- Poor: No systematic methods for identifying studies, major selection bias, or inappropriate methods for combining or pooling data

Quality criteria for systematic reviews are based on those developed by the USPSTF ^1^ and by Oxman and Guyatt.^2^

## Cost-effectiveness Studies

### Criteria

- Are interventions and populations compared appropriate?
- Is the study conducted from the societal perspective?
- Is the time horizon clinically appropriate and relevant to the study question?
- Are all important drivers of effectiveness included?
- Are key harms included?
- Is the best available evidence used to estimate effectiveness?
- Are long-term outcomes used?
- Do effects measured capture preferences or utilities?
- Are all appropriate downstream costs included?
- Are charges converted to costs appropriately?
- Are the best available data used to estimate costs?
- Are incremental cost-effectiveness ratios (ICERs) presented?
- Are appropriate sensitivity analyses performed?

Quality criteria for cost-effectiveness studies are based on those developed by the USPSTF for evaluation of cost effectiveness analyses.^3^ We used these criteria to guide our categorization of studies as good, fair, or poor. Quality grades were assigned based on a subjective assessment of study design and quality of data inputs.

#### References

1 Harris RP, Helfand M, Woolf SH, et al. Current methods of the third U.S. Preventive Services Task Force. Am J Prev Med. 2001;20(3S):21-35. [pmid: 11306229].
2 Oxman AD, Guyatt GH. Validation of an index of the qulaity of review articles. Journal of Clinical Epidemiology. 1991;44(11):1271-1278. [pmid: 1834807].
3 Saha S, Hoerger TJ, Pignone MP, Teutsch SM, Helfand M, Mandelblatt JS. The art and science of incorporating cost effectiveness into evidence-based recommendations for clinical preventive services. Am J Prev Med. 2001;20(3S):36-43. [pmid: 11306230].