# Evidence Tables

Evidence Table 1. Systematic Reviews Published Since 2004 on Effects of HIV Testing on Rates of Risky Behaviors or New Sexually Transmitted Infections

Author, year | Purpose of study | Databases searched, date of last search | Number of studies | Types of studies included/limitations of primary studies | Methods for rating quality of primary studies | Methods for synthesizing results of primary studies | Number of patients (treatment and control) | Interventions | Results | Adverse events | Quality rating
Marks, 2005^16^ | To compare the prevalence of high-risk sexual behaviors in HIV+ persons aware of their serostatus with that in HIV+ persons unaware of their status in the U.S. and to discuss implications for HIV prevention programs | MEDLINE, PubMed, PsycINFO, AIDSLINE, Sociofile (through January 2004) | 4 studies, 4 multi-site data sets. 11 findings described as independent. | 4 studies from peer-reviewed journals and 4 multisite data sets. Meta-analysis of 11 findings described as independent: 6 comparing HIV+ aware persons with independent groups of HIV+ unaware persons (between-group comparisons) and 5 comparing seroconverting persons before and after HIV+ status notification (within-subject comparisons). Outcomes: self-reported unprotected anal or vaginal intercourse (UAV) during specified recall periods. Limitations: lack of clearly defined inception cohorts, risk of attrition bias, no assessment of quality, no report of reasons studies were excluded, self-reported outcomes. | Quality not rated | A mathematical formula was used to calculate HIV transmission risk. Effect sizes were estimated with a prevalence ratio and a random-effects model was used for aggregating individual effect sizes. Sensitivity analyses were used for outliers and stratified analyses to control for type of comparison (between group vs within subject) and gender. An adjustment factor was applied to studies that assessed self-reported sexual behavior with any partner, and the analysis was conducted with and without this adjustment. This adjustment focused the analysis on behavior with partners at risk for infection. | Between group comparisons: | Notification of HIV+ serostatus | HIV+ aware versus HIV+ unaware | Not reported | Fair
| | Language: not specified. English only assumed | | | | | 12,468 HIV+ aware vs 894 HIV+ unaware | | Prevalence unprotected anal or vaginal intercourse with any partner: 53% lower (95% Cl 45% to 60%)
| | | | | | | Within subject comparisons: 343 HIV+ aware | | Prevalence unprotected anal or vaginal intercourse with partners not HIV+: 68% lower (95% Cl 59% to 76%)
Weinhardt, 2005^17^ | To review and synthesize empirical evidence of effects of HIV diagnosis on sexual risk behavior to determine: 1) What is the magnitude of reduction in sexual risk behavior resulting from an HIV diagnosis? 2) How long do reductions in risk behavior persist? 3) What needs to be done to maximize beneficial effects of an HIV diagnosis on transmission risk behavior? | MEDLINE, PsycINFO (through November 2003) | 23 | Included studies provided an assessment of when at least some participants received an HIV+ diagnosis relative to data collection, sexual behavior outcome data or a proxy measure, ≥ 2 assessments with the same participants, data from a sample independent from earlier included studies, summary or inferential statistics sufficient for calculation of within-group effect sizes. Limitations: self-reported sexual risk behaviors, lack of distinction between high risk sexual behavior and sexual behavior, no assessment of quality, risk of attrition bias, lack of information on study inclusion, poorly described content and duration of counseling. | Quality not rated | Effect sizes calculated (standardized mean difference index, d+) for sexual risk behaviors before and after HIV testing and counseling. These behaviors included: unprotected intercourse, condom use, and number of sexual partners. Effect size was estimated when only n and significance levels were available. Pooled standard deviation was used when only the mean and standard deviation were available.When dichotomous outcomes were reported, proportions were used as means and pooled standard deviations were derived. A correction for bias due to sample size was applied to calculated effect size. For each study, within-group effect sizes were computed separately for each sexual behavior outcome for each group (HIV+, HIV-, untested, serodiscordant couples, and mixed samples).Effect sizes for serodiscordant couples and mixed samples were calculated separately. Each participant was included in only 1 effect size for each outcome to avoid violating the assumption of independence of effect sizes. Fixed-effect procedures were used for analyses. The homogeneity of variance statistic Q was computed. | Final set of 62 effect sizes derived from 23 studies with a total population of 28,786. couples, HIV+ men: n=962 couples, HIV+ women: n=1120 couples, HIV+: n=310 couples, HIV-: n=970 couples, HIV status discordant: n=622 | Notification of HIV serostatus | All results reported as standardized effect sizes (d+); positive effect sizes indicate reduction in risky behaviors | Not reported | Fair
| | Language: not specified. English only assumed | | | | | HIV+ individuals: 3686 | | [underlined: Unprotected intercourse:]
| | | | | | | HIV- individuals: 10,915 | | Tested, HIV+: d+=0.44*; 95% Cl, 0.37 to 0.51
| | | | | | | untested individuals: 10,201 | | Serodiscordant couples: d+=0.85; 95%Cl, 0.71 to 0.99
| | | | | | | | | Untested: d+=0.13; 95% Cl, 0.07 to 0.18
| | | | | | | | | Tested, HIV-: d+=0.18*; 95% Cl, 0.12 to 0.23, p<.001
| | | | | | | | | [underlined: Condom use:]
| | | | | | | | | Tested, HIV+: d+=0.59; 95% Cl, 0.38 to 0.81
| | | | | | | | | Serodiscordant couples: d+=1.31*; 95% Cl, 1.14 to 1.48
| | | | | | | | | Untested: d+=0.49*, 95% Cl 0.37 to 0.61
| | | | | | | | | Tested, HIV-: d+=0.26, 95% Cl 0.11 to 0.41
| | | | | | | | | [underlined: Number of sexual partners:]
| | | | | | | | | Tested, HIV+: d+=0.34; 95% Cl, 0.20 to 0.47
| | | | | | | | | Tested, HIV-: d+=0.24*; 95% Cl, 0.15 to 0.34
| | | | | | | | | Untested: d+=0.07; 95% Cl, 0.03 to 0.18
| | | | | | | | | [underlined: HIV and STD incidence:]
| | | | | | | | | Tested, HIV+: d+=0.18, 95% Cl; 0.08 to 0.28
| | | | | | | | | Tested, HIV-: d+=-0.12, 95% Cl, -0.22 to -0.02
| | | | | | | | | Untested: d+=-0.05, 95% Cl, -0.09 to -0.01
| | | | | | | | | *Indicates significant (p<0.05) test for heterogeneity

Evidence Table 2. Quality Rating of Systematic Reviews Published Since 2004 on Effects of HIV Testing on Rates of Risky Sexual Behaviors or Sexually Transmitted Diseases

Author, year | Search methods reported | Search comprehensive | Inclusion criteria reported | Selection bias avoided | Validity criteria reported | Validity assessed appropriately | Methods used to combine studies reported | Findings combined appropriately | Conclusions supported by reported data | Overall scientific quality of review
Marks, 2005^16^ | Yes | Yes | Yes | Cannot tell -specific study exclusion reasons not provided | No (no QR) | No (sensitivity analysis, but no QR) | Yes | Cannot tell | Cannot tell | 2 – 3 major flaws
Weinhardt, 2005^17^ | Yes | Yes | Yes | Cannot tell - reason for exclusion provided for 2 studies - not clear if others were also excluded | No (no QR) | No (no QR) | Yes | Cannot tell | Cannot tell | 2 – 3 major flaws