# References

1 Chou R, Huffman LH, Fu R, Smits AK, Korthuis PT. Screening for human immunodeficiency virus in adolescents and adults (Evidence synthesis number 38). 2005. Accessed on September 22.
2 U.S. Preventive Services Task Force. Screening for HIV: Recommendation statement. Ann. Intern. Med. 2005;143:32–37.
3 Centers for Disease Control and Prevention. Revised recommendations for HIV testing of adults, adolescents, and pregnant women in health-care settings. Morb Mortal Wkly Rep. 2006;55(RR-14):1-17.
4 Glynn M, Rhodes P. Estimated HIV prevalence in the United States at the end of 2003. 2005 National HIV Prevention Conference. Atlanta, GA; 2005.
5 Fleming P, Byers RH, Sweeney PA, Daniels D, Karon JM, Janssen RS. HIV prevalence in the United States, 2000. The 9th Conference on Retroviruses and Opportunistic Infections. February 24–28. Seattle, WA: Foundation for Retrovirology and Human Health.; 2002.
6 Centers for Disease Control and Prevention. Cases of HIV infection and AIDS in the United States. HIV/AIDS Surveillance Report. 2005;16:16-45.
7 Centers for Disease Control and Prevention. Trends in HIV/AIDS diagnoses—33 states 2001-2004. MMWR. 2005;54(45):1149-53. [pmid: 16292247].
8 McNaghten AD, Hanson DL, Jones JL, Dworkin MS, Ward JW. Effects of antiretroviral therapy and opportunistic illness primary chemoprophylaxis on survival after AIDS diagnosis. Adult/Adolescent Spectrum of Disease Group. AIDS. 1999;13(13):1687-95. [pmid: 10509570].
9 Department of Health and Human Services. Guidelines for the use of antiretroviral agents in HIV-1-infected adults and adolescents 2006 May 4, 2006. Accessed.
10 Hammer SM, Saag MS, Schechter M, et al. Treatment for adult HIV infection: 2006 recommendations of the International AIDS Society—USA Panel. JAMA. 2006;296:827-43. [pmid: 16905788].
11 Centers for Disease Control and Prevention. Revised guidelines for HIV counseling, testing, and referral. Morb Mortal Wkly Rep. 2001;50(RR-19):1-57.
12 Harris RP, Helfand M, Woolf SH, et al. Current methods of the third U.S. Preventive Services Task Force. Am. J. Prev Med. 2001;20(3S):21-35. [pmid: 11306229].
13 Saha S, Hoerger TJ, Pignone MP, Teutsch SM, Helfand M, Mandelblatt JS. The art and science of incorporating cost effectiveness into evidence-based recommendations for clinical preventive services. Am. J. Prev Med. 2001;20(3S):36-43. [pmid: 11306230].
14 EXPLORE Study Team. Effects of a behavioural intervention to reduce acquisition of HIV infection amoung men who have sex with men: the EXPLORE randomised controlled study. Lancet. 2004;364:41-50. [pmid: 15234855].
15 Metcalf CA, Douglas JM, Malotte CK Jr, et al. Relative efficacy of prevention counseling with rapid and standard HIV testing: a randomized, controlled trial (RESPECT-2). Sex. Transm Dis. 2005;32(2):130-8. [pmid: 15668621].
16 Marks G, Crepaz N, Senterfitt JW, Janssen RS. Meta-analysis of high-risk sexual behavior in persons aware and unaware they are infected with HIV in the United States. JAIDS. 2005;39:446-53. [pmid: 16010168].
17 Weinhardt LS. HIV Diagnosis and Risk Behavior New York, New York: Kluwer Academic/Plenum Publishers; 2005. (Kalichman SC, ed. Positive Prevention. Reducing HIV Transmission among People LIving with HIV/AIDS).
18 Jenkins TC, Gardner EM, Thrun MW, et al. Risk-based human immunodeficiency virus (HIV) testing fails to detect the majority of HIV-infected persons in medical care Settings. Sex. Transm. Dis. 2006;33(5):329-33. [pmid: 16547450].
19 Weinhardt LS, Carey MP, Johnson BT, Bickham NL. Effects of HIV counseling and testing on sexual risk behavior: a meta-analytic review of published research, 1985-1997. Am. J Public Health. 1999;89(9):1397-405. [pmid: 10474559].
20 Kaiser Family Foundation. Survey of Americans on HIV/AIDS. Washinton, DC. Kaiser Family Foundation; 2006. Available at http://www.kff.org/kaiserpolls/7521.cfm. 2006.
21 Wurcel A, Zaman T, Zhen S, et al. Acceptance of HIV antibody testing among inpatients and outpatients at a public health hospital: a study of rapid versus standard testing. AIDS Patient Care & Stds. 2005;19(8):499-505. [pmid: 16124844].
22 Marks G, Crepaz N, Janssen RS. Estimating sexual transmission of HIV from persons aware and unaware that they are infected with the virus in the USA. AIDS. 2006;20:1447-50. [pmid: 16791020].
23 Walensky RP, Weinstein MC, Smith HE, et al. Optimal allocation of testing dollars: the example of HIV counseling, testing, and referral. Med. Decis Making. 2005;25(3):321-9. [pmid: 15951459].
24 US Preventive Services Task Force. Guide to Clinical Preventive Services: Agency for Healthcare Research and Quality; 1996. Accessed at http://www.ahrq.gov/clinic/2ndcps/hiv.pdf on March 8, 2007.
25 Weinhardt LS, Kelly JA, Brondino MJ, et al. HIV transmission risk behavior among men and women living with HIV in 4 cities in the United States. J. Acquir. Immune Defic Syndr. 2004;36(5):1057-66. [pmid: 15247559].
26 Centers for Disease Control and Prevention. Prevalence of risk behaviors for HIV infection among adults - United States, 1997. Morb Mortal Wkly Rep. 2001;50(14):262-65.
27 Anderson JE, Mosher WD, Chandra A. Measuring HIV risk in the U.S. population aged 15–44: Results from cycle 6 of the National Survey of Family Growth. Advance Data. 2006;377:1-28. [pmid: 17094643].
28 Centers for Disease Control and Prevention. Youth risk behavior surveillance-United States, 2005. In: CDC Surveillance Summaries. MMWR. 2006;55(No. SS-5):1-108.
29 Rawitscher LA, Saitz R, Friedman LS. Adolescents' preferences regarding human immunodeficiency virus (HIV)-related physician counseling and HIV testing. Pediatrics. 1995;96:52-58. [pmid: 7596723].
30 Gerbert B, Macguire BT, Coates TJ. Are patients talking to their physicians about AIDS?. Am. J Public Health. 1990;80:467-8. [pmid: 2316771].
31 Gerbert B, Bronstone A, McPhee S, Pantilat S, Allerton M. Development and testing of an HIV-risk screening instrument for use in health care settings. Am. J. Prev Med. 1998;15(2):103-13. [pmid: 9713665].
32 Gerbert B, Brown B, Volberding P, et al. Physicians' transmission prevention assessment and counseling practices with their HIV positive patients. AIDS Educ Prev. 1999;11(4):307-20. [pmid: 10494355].
33 Klein D, Hurley LB, Merrill DP, Quesenberry CP Jr. Review of medical encounters in the 5 years before a diagnosis of HIV-1 infection: implications for early detection. J. Acquir. Immune Defic Syndr. 2003;32(2):143-52. [pmid: 12571523].
34 Liddicoat RV, Horton NJ, Urban R, Maier E, Christiansen D, Samet JH. Assessing missed opportunities for HIV testing in medical settings. J. Gen. Intern Med. 2004;19(4):349-56. [pmid: 15061744].
35 Peterman TA, Todd KA, Mupanduki I. Opportunities for targeting publicly funded human immunodeficiency virus counseling and testing. J. Acquir. Immune Defic. Syndr. Hum Retrovirol. 1996;12(1):69-74. [pmid: 8624764].
36 Chen Z, Branson B, Ballenger A, Peterman TA. Risk assessment to improve targeting of HIV counseling and testing services of STD clinic patients. Sex. Transm Dis. 1998;25(10):539-43. [pmid: 9858350].
37 Harris RL, Boisaubin EV, Salyer PD, Semands DF. Evaluation of a hospital admission HIV antibody voluntary screening program. Infect. Control Hosp Epidemiol. 1990;11(12):628-34. [pmid: 2125612].
38 Centers for Disease Control and Prevention. Voluntary HIV testing as part of routine medical care - Massachusetts, 2002. Morb Mortal Wkly Rep. 2004;53(24):523-6.
39 Centers for Disease Control and Prevention. Routinely recommended HIV testing at an urban urgent-care clinic—Atlanta, Georgia, 2000. Morb Mortal Wkly Rep. 2001;50(25):538-41.
40 Walensky RP, Losina E, Steger-Craven KA, Freedberg KA. Identifying undiagnosed human immunodeficiency virus: the yield of routine, voluntary inpatient testing. Arch. Intern Med. 2002;162(8):887-92. [pmid: 11966339].
41 Goggin MA, Davidson AJ, Cantril SV, O'Keefe LK, Douglas JM. The extent of undiagnosed HIV infection among emergency department patients: results of a blinded seroprevalence survey and a pilot HIV testing program. J. Emerg Med. 2000;19(1):13-9. [pmid: 10863112].
42 Centers for Disease Control and Prevention. Number of persons tested for HIV—United States, 2002. Morb Mortal Wkly Rep. 2004;53(47):1110-13.
43 Abma JC, Chandra A, Mosher W, et al. Fertility, family planning, and women's health: new data from the 1995 National Survey of Family Growth. Vital Health Stat 23. 1997;19:1-114. [pmid: 9201902].
44 Liddicoat RV, Losina E, Kang M, Freedberg KA, Walensky RP. Refusing HIV testing in an urgent care setting: results from the “Think HIV” program. AIDS Patient Care & Stds. 2006;20(2):84-92. [pmid: 16475889].
45 Irwin KL, Valdiserri RO, Holmberg SD. The acceptability of voluntary HIV antibody testing in the United States: a decade of lessons learned. AIDS. 1996;10(14):1707-17. [pmid: 8970692].
46 Stanley B, Fraser J, Cox NH. Uptake of HIV screening in genitourinary medicine after change to “opt-out” consent. BMJ. 2003;326(7400):1174. [pmid: 12775616].
47 Liang TS, Erbelding E, Jacob CA, et al. Rapid HIV testing of clients of a mobile STD/HIV clinic. AIDS Patient Care & Stds. 2005;19(4):253-7. [pmid: 15857197].
48 Centers for Disease Control and Prevention. HIV counseling and testing in publicly funded sites Annual Report 1997 and 1998. 2001. Accessed at http://www.cdc.gov/hiv/pubs/cts98.pdf on March 3, 2005.
49 Centers for Disease Control and Prevention. Protocols for confirmation of reactive rapid HIV tests. Morb Mortal Wkly Rep. 2004;53(10):221-22.
50 Kassler WJ. Advances in HIV testing technology and their potential impact on prevention. AIDS Educ Prev. 1997;9(3 Suppl):27-40. [pmid: 9241396].
51 Kelen GD, Shahan JB, Quinn TC. Emergency department-based HIV screening and counseling: experience with rapid and standard serologic testing. Ann. Emerg Med. 1999;33(2):147-55. [pmid: 9922409].
52 Centers for Disease Control and Prevention. Supplement to HIV/AIDS surveillance (SHAS): demographics and behavioral data from a supplemental HIV/AIDS behavioral surveillance project 1997-2000. 2004 [2]. Accessed at http://www.cdc.gov/hiv/topics/surveillance/resources/reports/2004spec_no2/cover.htm on October 17.
53 Bozzette SA, Berry SH, Duan N, et al. The care of HIV-infected adults in the United States. N. Engl. J Med. 1998;339(26):1897-904. [pmid: 9862946].
54 Kaplan EH, Satten GA. Repeat screening for HIV: when to test and why. J. Acquir. Immune Defic Syndr. 2000;23(4):339-45. [pmid: 10836757].
55 Sanders GD, Bayoumi AM, Sundaram V, et al. Cost-effectiveness of screening for HIV in the era of highly active antiretroviral therapy. N. Engl. J Med. 2005;352(6):570-85. [pmid: 15703422].
56 Paltiel AD, Weinstein MC, Kimmel AD, et al. Expanded screening for HIV in the United States—an analysis of cost-effectiveness. N. Engl. J Med. 2005;352(6):586-95. [pmid: 15703423].
57 Holtgrave DR. Estimation of annual HIV transmission rates in the United States, 1978-2000. J. Acquir. Immune Defic Syndr. 2004;35(1):89-92. [pmid: 14707798].
58 Padian NS, O'Brien TR, Chang Y, Glass S, Francis DP. Prevention of heterosexual transmission of human immunodeficiency virus through couple counseling. J. Acquir. Immune Defic Syndr. 1993;6(9):1043-8. [pmid: 8340895].
59 Allen S, Tice J, Van de Perre P, et al. Effect of serotesting with counselling on condom use and seroconversion among HIV discordant couples in Africa. BMJ. 1992;304(6842):1605-9. [pmid: 1628088].
60 Quinn TC, Wawer MJ, Sewankambo N, et al. Viral load and heterosexual transmission of human immunodeficiency virus type 1. N. Engl. J Med. 2000;342(13):921-9. [pmid: 10738050].
61 Murphy G, Charlett A, Jordan LF, Osner N, Gill ON, Parry JV. HIV incidence appears constant in men who have sex with men despite widespread use of effective antiretroviral therapy. AIDS. 2004;18(2):265-72. [pmid: 15075544].
62 Crepaz N, Hart TA, Marks G. Highly active antiretroviral therapy and sexual risk behavior. JAMA. 2004;292(2):224-36. [pmid: 15249572].
63 George N, Green J, Murphy S. Sexually transmitted disease rates before and after HIV testing. Int. J STD AIDS. 1998;9:291-93. [pmid: 9639207].
64 Otten MW Jr, Zaidi AA, Wroten JE, Witte JJ, Peterman TA. Changes in sexually transmitted disease rates after HIV testing and posttest counseling, Miami, 1988 to 1989. Am. J Public Health. 1993;83(4):529-33. [pmid: 8460729].
65 Chamot E, Coughlin SS, Farley TA, Rice JC. Gonorrhea incidence and HIV testing and counseling among adolescents and young adults seen at a clinic for sexually transmitted diseases. AIDS. 1999;13(8):971-9. [pmid: 10371179].
66 Wingood GM, DiClemente RJ, Mikhail I, et al. A randomized controlled trial to reduce HIV transmission risk behaviors and sexually transmitted diseases among women living with HIV. J. Acquir. Immune Defic Syndr. 2004;37(2 Suppl):S58-S67. [pmid: 15385901].
67 Kamb ML, Fishbein M, Douglas JM Jr, et al. Project RESPECT Study Group. Efficacy of risk-reduction counseling to prevent human immunodeficiency virus and sexually transmitted diseases: a randomized controlled trial. JAMA. 1998;280(13):1161-7. [pmid: 9777816].
68 Ciccarone DH, Kanouse DE, Collins RL, et al. Sex without disclosure of positive HIV serostatus in a US probability sample of persons receiving medical care for HIV infection. Am. J Public Health. 2003;93:949-54. [pmid: 12773361].
69 Centers for Disease Control and Prevention. Gonorrhea among men who have sex with men - selected sexually transmitted diseases clinics, 1993-1996. Morb Mortal Wkly Rep. 1997;46(38):889-92.
70 Centers for Disease Control and Prevention. Resurgent bacterial sexually transmitted disease among men who have sex with men - King County, Washington, 1997-1999. Morb Mortal Wkly Rep. 1999;48(35):773-7.
71 Centers for Disease Control and Prevention. Increases in unsafe sex and rectal gonorrhea among men who have sex with men - San Francisco, California, 1994-1997. Morb Mortal Wkly Rep. 1999;48(3):45-8.
72 Centers for Disease Control and Prevention. Trends in primary and secondary syphilis and HIV infections in men who have sex with men - San Francisco and Los Angeles, California, 1998-2002. Morb Mortal Wkly Rep. 2004;53(26):575-8.
73 Centers for Disease Control and Prevention. High-risk sexual behavior by HIV-positive men who have sex with men—16 sites, United States, 2000-2002. MMWR Morb. Mortal. Wkly. Rep. 2004;53(38):891-94. [pmid: 15457144].
74 Do AN Hanson DL Dworkin MS Jones JL Adult and Adolescent Spectrum of HIV Disease Project Investigators. Risk factors for and trends in gonorrhea incidence among persons infected with HIV in the United States AIDS 2001 15 9 1149 55.11416717
75 Webster RD, Darrow WW, Paul JP, et al. Community planning, HIV prevention, and a needs assessment for men who have sex with men: the South Beach Health Survey. Sex. Transm Dis. 2005;32(5):321-7. [pmid: 15849534].
76 Higgins DL, Galavotti C, O'Reilly KR, et al. Evidence for the effects of HIV antibody counseling and testing on risk behaviors. JAMA. 1991;266(17):2419-29. [pmid: 1920748].
77 Wolitski RJ, MacGowan RJ, Higgins DL, Jorgenson CM. The effects of HIV counseling and testing on risk-related practices and help-seeking behavior. AIDS Educ Prev. 1997;9(Suppl. B):52-67. [pmid: 9241398].
78 Weinhardt LS, Forsyth AD, Carey MP, Jaworski BC, Durant LE. Reliability and validity of self-report measures of HIV-related sexual behavior: progress since 1990 and recommendations for research and practice. Archives of Sexual Behavior. 1998;27(2):155-80. [pmid: 9562899].
79 Cleary PD, Van Devanter N, Rogers TF, et al. Behavior changes after notification of HIV infection. Am. J. Public Health. 1991;81(12):1586-90. [pmid: 1746654].
80 Colfax GN, Buchbinder SP, Cornelisse PG, Vittinghoff E, Mayer K, Celum C. Sexual risk behaviors and implications for secondary HIV transmission during and after HIV seroconversion. AIDS. 2002;16(11):1529-35. [pmid: 12131191].
81 McCusker J, Stoddard AM, Mayer KH, Zapka J, Morrison C, Saltzman SP. Effects of HIV antibody test knowledge on subsequent sexual behaviors in a cohort of homosexually active men. Am. J Public Health. 1988;78:462-67. [pmid: 3162357].
82 Rotheram-Borus MJ, Lee MB, Murphy DA, et al. Efficacy of a preventive intervention for youths living with HIV. Am. J Public Health. 2001;91(3):400-05. [pmid: 11236404].
83 Fogarty LA, Heilig CM, Armstrong K, et al. Long-term effectiveness of a peer-based intervention to promote condom and contraceptive use among HIV-positive and at-risk women. Public Health Rep. 2001;116(Suppl 1):103-19. [pmid: 11889279].
84 Kalichman SC, Rompa D, Cage M, et al. Effectiveness of an intervention to reduce HIV transmission risks in HIV-positive people. Am. J. Prev Med. 2001;21(2):84-92. [pmid: 11457627].
85 Wawer MJ, Gray RH, Sewankambo NK, et al. Rates of HIV-1 transmission per coital act, by stage of HIV-1 infection, in Rakai, Uganda. Journal of Infectious Diseases. 2005;191(9):1403-9. [pmid: 15809897].
86 Weller S, Davis K. Condom effectiveness in reducing heterosexual HIV transmission (Cochrane Review). In: The Cochrane Library. Chichester, UK: John Wiley & Sons, Ltd.; 2004.
87 Pinkerton SD, Abramson PR. Effectiveness of condoms in preventing HIV transmission. Soc. Sci Med. 1997;44(9):1303-12. [pmid: 9141163].
88 Friis-Moller N, Sabin CA, Weber R, et al. Combination antiretroviral therapy and the risk of myocardial infarction. N. Engl. J Med. 2003;349(21):1993-2003. [pmid: 14627784].
89 Chou R, Smits AK, Huffman LH, Fu R, Korthuis PT. Screening for human immunodeficiency virus in pregnant women: systematic evidence synthesis (in press). 2005. Accessed at http://www.ahrq.gov/clinic/uspstfix.htm.
90 Centers for Disease Control and Prevention. HIV counseling with rapid tests. Accessed at http://www.cdc.gov/hiv/topics/testing/resources/factsheets/rt_counseling.htm on November 3.
91 Delaney KP, Branson BM, Uniyal A, et al. Performance of an oral fluid rapid HIV-1/2 test: experience from four CDC studies. AIDS. 2006;20:1655-60. [pmid: 16868447].
92 Wesolowski LG, MacKellar DA, Facente SN, et al. Post-marketing surveillance of OraQuick whole blood and oral fluid rapid HIV testing. AIDS. 2006;20:1661-66. [pmid: 16868448].
93 Health Research and Educational Trust. Map to HIV testing laws of all U.S. states. Chicago, IL: American Hospital Association. Available at http://www/hret.org/hret/about/map.html. 2006.
94 Centers for Disease Control and Prevention. Advancing HIV prevention: New strategies for a changing epidemic—United States, 2003. Morb Mortal Wkly Rep. 2003;52(15):329-32.