# Results

## Can Risk Factor Assessment Identify Asymptomatic Adolescents and Adults at Increased Risk for HIV Compared to the General Population?

Risk factors for HIV infection are unchanged since the USPSTF first issued recommendations for HIV screening in 1996.^24^ Persons at higher risk for HIV infection include those seeking treatment for sexually transmitted diseases; men who have had sex with men after 1975; past or present injection drug users; persons who exchange sex for money or drugs, and their sex partners; women and men whose past or present sex partners were HIV-infected, bisexual individuals, or injection drug users; and persons with a history of transfusion between 1978 and 1985.^24^ The CDC also considers persons who themselves or whose sex partners have had more than one sex partner since their most recent HIV test as high risk.^3^

Updated surveillance data from the CDC indicates that from 2001 through 2004, 61% of new diagnoses of HIV or AIDS in U.S. males were associated with male-to-male sex, 17% with heterosexual contact, 16% with intravenous drug use, 5% with intravenous drug use by men who have sex with men, and 1% with other risk factors.^7^ Among females, the most prevalent exposure categories were heterosexual contact (76%) and injection drug use (21%). Non-Hispanic blacks account for 68% of new HIV diagnoses in females and 44% in males.^7^

In the 2005 evidence synthesis, we summarized evidence suggesting that a significant proportion of American adults and adolescents report behaviors that could put them at risk for HIV infection.^25,^ ^26^ New data from the National Center for Health Statistics estimates that 11.9% of persons between 15 and 44 years of age had engaged in sexual or drug use behaviors in the past year that put them at increased risk of HIV, or had been treated for a sexually transmitted disease.^27^ About one-third had never been tested for HIV. Results from the Youth Risk Behavior Surveillance System found that in 2005, 47% of high school students reported ever having sexual intercourse, and 37% of sexually active high school students had not used a condom during last sexual intercourse.^28^ A small proportion (2.1%) of high school students reported ever using a needle to inject an illegal drug into their body.

We found no new studies evaluating willingness to disclose high risk behaviors in low-prevalence or primary care settings. Previous studies included in the 2005 evidence synthesis indicate that most adolescents^29^ and adults^30^ are willing to discuss and disclose high risk behaviors when asked about them.^31,^ ^32^ Even in settings with good access to medical care, however, high-risk behaviors frequently remain undetected and do not necessarily lead to testing even when identified.^33,^ ^34^

We found no new studies evaluating the proportion of HIV-positive patients reporting risk factors in low-risk settings. One new retrospective study found that 28% (33/120) of newly diagnosed HIV-infected persons in the Denver public health system had an HIV clinical indicator condition or sexually transmitted infection, but it did not assess for the presence of HIV risk factors.^18^ In the 2005 evidence synthesis, we reviewed data from the largest U.S. study on HIV testing, which found that 20% of HIV-positive clients at federally funded HIV testing sites with a prevalence of 0.1% to 2.0% reported no risk factors.^35^ The rate of HIV positivity in patients reporting no risk factors ranged from 0.2% to 0.8% in these sites.

We found no new studies comparing the proportion of HIV-infected persons diagnosed using targeted versus universal screening strategies in low-risk or other settings. In the only prospective study included in the 2005 evidence synthesis, screening only those patients in an STD clinic setting reporting risky behaviors (5.8% of the population) would have resulted in missed diagnoses in 74% (79/107) of cases.^36^ A strategy that also included testing of all patients from higher-prevalence demographic groups (black males and age >30 years) would have resulted in fewer (7%) missed diagnoses, but substantially more testing (70% of the population). However, this study did not include unprotected sexual intercourse with partners not known to be at high risk for HIV infection as a risk factor. Multiple retrospective and cross-sectional studies in diverse settings that were reviewed in the 2005 evidence synthesis also found that significant proportions of HIV-infected persons reported no risk factors, though estimates ranged from 7% to 51%.^1^ Factors that could explain some of the variation in rates of identifiable risk factors include population differences, varying stringency of risk factor ascertainment, or use of different definitions for HIV risk factors (such as whether more than one sexual partner or any unprotected heterosexual intercourse were considered risk factors).

We also found no new studies evaluating the effects of implementation of routine voluntary screening in low-risk settings. In one older study at an average-risk hospital, 51% (4535/8868) patients agreed to voluntary testing, and 0.26% (12 of 4535) tested positive.^37^ Ten of the twelve HIV-positive persons (83%) were considered high-risk. Several other studies included in the 2005 evidence synthesis reported increased numbers of new HIV diagnoses after the implementation of routine voluntary screening in higher-risk settings (prevalence >1%).^38^–^41^

## Is Routine Voluntary Screening Acceptable to Patients?

Approximately half of U.S. adults report having been tested at least once for HIV.^20,^ ^42^ In one new national survey, 21% had been tested within the last 12 months.^20^ The proportion of adolescents tested for HIV infection is substantially lower than for those aged 18 or older.^43^

We identified no new studies evaluating the acceptability of routine, voluntary HIV antibody testing in low-risk settings. One new study of routine voluntary HIV testing in four high-prevalence (2%) urgent care centers found that 67% of 9,129 patients refused testing.^44^ Of those who gave one reason for test refusal, 43% refused because they did not feel that they were high risk, 1% felt that the information was too personal, and 4% felt testing would take too long. The site with the longest-standing routine testing policy had the lowest rate of test refusal (47% versus 75–87% at the other three sites). One potential explanation for this finding is that HIV test uptake rates may increase over time, as routine testing becomes normalized in a particular setting. However, such a hypothesis needs to be confirmed, as numerous other factors could affect testing rates across sites.

One older, good-quality systematic review of 62 studies on the acceptability of HIV antibody testing in the U.S., included in the 2005 evidence synthesis, found lower prevalence settings associated with lower acceptance rates, though estimates varied widely.^45^ For example, in family planning clinics, test uptake rates ranged from 14% to 67%. Several recent studies included in the 2005 evidence synthesis evaluated the implementation of routine voluntary HIV testing policies in higher risk settings. In one study, testing rates increased approximately three-fold (to 6.4%) in an inpatient urban hospital.^40^ However, the proportion of patients offered and refusing testing were not reported. In studies evaluating routine testing policies in urgent care and emergency room settings, testing rates ranged from 1.8% to 32%.^38,^ ^39,^ ^41^

CDC's 2001 guidelines for HIV testing recommended fairly extensive pre-test counseling.^11^ A new, national survey by the Kaiser Family Foundation found that approximately two-thirds of 2,517 respondents agreed with a statement that HIV testing should be treated just like routine screening for other diseases.^20^ On the other hand, about one-quarter agreed with a statement that HIV testing should require special procedures, such as written permission from the patient. Data on the effects of streamlined counseling on uptake rates remains sparse. No new studies evaluated the acceptability or effects of ‘opt-out’ testing policies (notifying people that an HIV test is routine and performing it unless refused) in non-pregnant, low-risk adults or adolescents in the U.S. One study from a low-prevalence STD clinic in the U.K., included in the 2005 evidence synthesis, found that test uptake increased from 35% to 65% after implementing opt-out testing.^46^ We found no new studies assessing the effects of anonymous versus confidential or name-based testing.

The use of more convenient, less invasive, or rapid tests could improve HIV testing acceptability. One new randomized trial of outpatients and inpatients found a trend towards a higher rate of test uptake in patients randomized to a rapid HIV test versus conventional testing (60/101 or 59%, versus 42/102 or 41%, p=0.07).^21^ In this trial, more than 90% of patients reported at least one risk factor (including unprotected heterosexual intercourse). A recent Kaiser Family Foundation survey found that 62% of respondents would prefer to be tested for HIV in a doctor's office or clinic, versus 26% at home.^20^ We found no other new studies in low-risk settings evaluating preferences for home sample collection kits, telephone-based counseling, rapid tests, on-site testing, or non-invasive tests compared to standard office-based blood testing. These methods were generally preferred over standard office-based testing in studies, most in higher-risk settings, reviewed in the 2005 evidence synthesis. One new study in a mobile sexually transmitted disease/HIV clinic found that 64% of subjects offered rapid or standard testing chose the former.^47^

## Does Routine Voluntary Screening Increase the Proportion of HIV-Positive Patients Entering Care or Result in Earlier Diagnosis?

HIV-positive patients who qualify for interventions may not receive them. In a large study of publicly funded testing sites across the U.S., 44% of all tested patients and 38% of those with a positive test result did not have a post-test counseling session.^48^ The proportion of patients informed of test results could be increased by the use of rapid tests, which provide results within 10 to 30 minutes. Although positive results need to be confirmed by further testing,^49^ patients can be given initial results prior to leaving the testing site. One recent randomized trial of inpatients and outpatients at a public health hospital found that more patients randomized to rapid testing were informed of their results compared to those randomized to standard testing (95% vs. 43%, p<0.001).^21^ We identified no other new studies evaluating the proportion of HIV-positive persons learning their serostatus in low-risk settings. In studies of patients in high-risk settings included in the 2005 evidence synthesis, rapid testing was consistently associated with a higher rate of HIV-positive persons learning their serostatus, compared to standard testing.^47,^ ^50,^ ^51^

HIV-positive patients may delay entry into medical care or not receive care at all.^52^ In 1996, only an estimated 36% to 63% of patients with known or unknown HIV infection were seeing a provider outside an emergency room at least once every 6 months.^53^ We found no new studies evaluating the proportion of newly diagnosed patients in low-risk settings who entered into care. One study included in the 2005 evidence synthesis found that only 35% (26/74) of newly diagnosed HIV-infected persons identified through a routine voluntary screening program in a high-prevalence urgent care center had entered care within four months.^39^. However, in another study, at least 70% (42/60) of newly diagnosed HIV-infected persons had one or more documented follow-up visits.^38^ Rates of entry into care are likely to vary across different settings, in part due to population characteristics and differences in the resources and models used to enhance rates of follow-up.

Studies summarized in the 2005 evidence synthesis indicate that a high proportion of HIV-infected patients are diagnosed at late stages of disease.^1^ We identified no new studies estimating the effects of screening on the proportion of patients with HIV infection identified shortly before being diagnosed with AIDS or concurrently with their AIDS diagnosis.

## How Effective Is Repeat Testing in Identifying Additional Cases of HIV Infection and Improving Clinical Outcomes?

We identified no new studies evaluating the effectiveness of repeat testing, or determining optimal testing intervals,,for identifying new cases of HIV infection in non-pregnant adults and adolescents in low-risk or other settings. The optimal frequency of testing will vary depending on the incidence of undetected HIV infection in the group being tested (prevalent cases would be identified on initial screening).^54^ Two good-quality cost-effectiveness analyses included in the 2005 evidence synthesis found screening every five years in a population with 1% prevalence cost less than $50,000 per quality-adjusted life-year only when secondary transmission benefits were included and annual incidence was at least 0.09%.^55,^ ^56^ in low-prevalence (0.1% undiagnosed HIV infection) settings, one of these studies found repeat screening at any interval cost more than $100,000 per quality-adjusted life-year at all plausible incidences.^56^ This study also found that in a high-risk setting (incidence 1.20% per year and prevalence 3.0%), screening every five years cost $50,000 per quality-adjusted life year relative to one-time screening, and screening every three years or annually cost more than $60,000 per quality-adjusted life-year compared to less frequent screening strategies.

## How Effective Is HIV Screening in Reducing Transmission Rates of HIV or Other Sexually Transmitted Diseases?

Theoretically, HIV testing and counseling could reduce HIV transmission rates through a reduction in risky behaviors. However, direct evidence on the impact of HIV testing and counseling on HIV transmission rates remains sparse. We identified no new studies comparing rates of HIV transmission from tested and untested persons. An epidemiologic study included in the 2005 evidence synthesis estimated that the annual HIV transmission rate from HIV-seropositive persons in the United States declined from 13% in 1987 (the year zidovudine was introduced) to 5.5% in 1989, but has remained steady at approximately 4.2% from 1990 through 2000.^57^ The 2005 evidence synthesis also included one prospective U.S. study of 144 serodiscordant heterosexual couples who received counseling and reported reduced risky behaviors. The study found no seroconversion after 193 couple-years of follow-up.^58^ However, because of possible underlying factors impeding transmission, data from monogamous serodiscordant couples may not be applicable to the general population of patients with HIV infection. An older, prospective African study found a rate of seroconversion among uninfected female partners of HIV-positive men of 6–9/100 person-years, compared to 22/100 person-years among uninfected women with untested partners.^59^

HIV counseling and testing could also reduce HIV transmission indirectly, by identifying additional patients who meet criteria for antiretroviral therapy. HAART could decrease the spread of HIV from infected persons by reducing viral loads.^60^ On the other hand, increases in risky behaviors by patients on HAART could attenuate or offset the beneficial effects of viral suppression.^61^ We identified no new studies estimating effects of HAART on horizontal transmission rates. In the 2005 evidence synthesis, we included one good-quality meta-analysis of 25 studies that found no association between receipt of HAART or having an undetectable viral load and an increased likelihood of unprotected sex, but among seronegative and seropositive persons, unprotected intercourse was associated with optimistic beliefs about HAART or an undetectable viral load (OR 1.82, 95% CI, 1.52–2.17).^62^

One fair-quality systematic review of observational studies (an update of a study included in the 2005 evidence synthesis^19^) included an analysis of rates of sexually transmitted diseases (a clinical marker for risky behaviors) following HIV testing, based on searches conducted through November 2003 (Evidence Table 1).^17^ It did not assess the quality of the included studies (Evidence Table 2). Data on sexually transmitted disease rates could only be pooled from two studies.^63,^ ^64^ The incidence of new sexually transmitted diseases decreased modestly among individuals testing HIV-positive (standardized effect size [d+] = 0.18, 95% CI 0.08 to 0.28), but increased modestly among individuals testing negative (d+ = -0.12, 85% CI -0.22 to -0.02) and those untested (d+ = -0.05, 95% CI -0.09 to -0.01). A third study, which could not be pooled, was a retrospective cohort study of primarily young (ages 15 to 25 years) black persons in a sexually transmitted disease clinic setting. This study found an increase in gonorrhea rates relative to pre-test rates among those who tested HIV-negative and received post-test counseling (RR 1.27, 95% CI 1.09 to 1.48), and no significant difference in gonorrhea rates among those testing positive (RR 0.53, 95% CI 0.17 to 1.60).^65^ All three studies were retrospective and had unclear rates of loss to follow-up.

More intensive or targeted HIV counseling could be more effective than standard counseling in reducing sexually transmitted diseases or HIV infection rates, but would require additional resources. We identified no new studies evaluating the effectiveness of more intensive or targeted HIV counseling in reducing sexually transmitted diseases or HIV infection rates in HIV-positive persons. In the single randomized controlled trial of HIV-positive persons included in the 2005 evidence synthesis, more intensive counseling was associated with fewer sexually transmitted diseases than standard counseling in 366 infected women.^66^ One new randomized trial (RESPECT-2) found no differences in the risk for new sexually transmitted diseases in HIV-negative persons at STD clinics, following counseling and testing with a rapid versus a standard HIV test (RR 1.11, 95% CI 0.96 to 1.29).^15^ Another new trial (the EXPLORE study) found a trend towards a lower rate of HIV infection among 4,295 HIV-negative men who have sex with men, among those receiving more intensive versus less intensive individualized counseling after 48 months (rate difference 18.2%, 95% CI -4.7 to 36.0%), with the largest effects in the first 12 to 18 months.^14^ A large trial (n=5,758) of heterosexual, HIV-negative persons, included in the 2005 evidence synthesis, found interactive HIV counseling and testing associated with 20% fewer sexually transmitted diseases after twelve months than standard non-interactive didactic counseling and testing; however, no significant difference was found between the counseling groups in the rate of new HIV infections (eight total).^67^

## How Effective Is HIV Screening in Reducing Rates of Risky Behaviors?

In the 2005 evidence synthesis, we summarized evidence indicating that a significant proportion of HIV-infected persons engage in ongoing behaviors that increase the risk of transmitting the disease, such as using condoms inconsistently, having multiple sexual partners, engaging in injection drug use, or trading sex for drugs or money.^52^ For example, one recent survey found that 13–19% of HIV-infected persons (n=3723) reported unprotected vaginal or anal intercourse with partners HIV-negative or of unknown serostatus.^25^ Another survey of HIV-positive persons (n=1,421) found that 13% reported unprotected anal or vaginal intercourse without disclosure of HIV status.^68^ In several epidemiological studies (with data collected through 2002), risky behaviors and STD rates appeared resurgent among certain highly tested populations of men who have sex with men.^25,^ ^69^–^75^

We identified one new systematic review comparing the rates of self-reported unprotected anal or vaginal intercourse of HIV-positive persons aware and unaware of their status (Evidence Table 1).^16^ Four of the eight studies that were included (no randomized trials) evaluated men who have sex with men, and another primarily evaluated female intravenous drug users. The systematic review was rated only fair quality, because it did not assess the quality of included studies or report reasons for excluding studies (Evidence Table 2). In addition, unpublished data from four studies was used in the analysis, but there was insufficient detail about methods to judge their quality. The meta-analysis found self-reported rates of unprotected anal or vaginal intercourse with any partner an average of 53% lower (95% CI 45% to 60%) in patients aware of their HIV-positive status, compared to those unaware. There was a 68% reduction (95% CI 56% to 76%) when the analysis was adjusted to focus on unprotected intercourse with serodiscordant partners.

We also identified an update of an earlier systematic review^19^ (included in the 2005 evidence synthesis) that included 23 observational studies published in November 2003 or earlier, on the effects of HIV counseling and testing on risky behaviors in patients testing HIV-positive or -negative and in untested persons (Evidence Table 1).^17^ This update also did not assess the quality of included studies (Evidence Table 2). It found self-reported reductions in unprotected intercourse greater for persons testing HIV-positive (standardized effect size [d+] = 0.44, 95% CI 0.37 to 0.51) and for serodiscordant couples (d+ = 0.85, 95% CI 0.71 to 0.99) than for untested persons (d+ = 0.13, 95% CI 0.07 to 0.18) or those testing HIV-negative (d+ = 0.18, 95% CI 0.12 to 0.23). The number of self-reported sexual partners decreased more in persons testing HIV-positive (d+ = 0.34, 95% CI 0.20 to 0.47) or -negative (d+=0.24, 95% CI 0.15 to 0.34) than in untested persons (d+ = 0.07, 95% CI 0.03 to 0.18). These estimates are similar to earlier estimates based on studies published through 1997.^19^

Two other older systematic reviews were included in the 2005 evidence synthesis.^76,^ ^77^ Both found testing and counseling most effective in reducing risky behaviors (primarily rates of unprotected intercourse or condom use) among serodiscordant heterosexual couples and those testing HIV-positive, with less evidence for beneficial effects in other populations.

Interpreting the results of all the systematic reviews is difficult because the primary studies evaluated diverse populations, employed different counseling interventions, and frequently had methodological shortcomings. Reasons for testing were not reported, and it is not clear if the results are generalizable to asymptomatic patients who would be identified by screening. In addition, all the studies were conducted when guidelines recommended extensive pre-test counseling prior to HIV testing, and may not be generalizable to streamlined HIV screening without prevention counseling as recommended in the 2006 CDC recommendations. The content and duration of counseling was generally poorly described and varied dramatically between studies, and in some cases may have varied within studies.^17^ Most studies used older counseling approaches and measured self-reported behavior changes, which could lead to over-reporting of socially desirable responses (reductions in risky behaviors).^78^ None of the studies reported attempts to verify self-reported behaviors (by methods such as checking concordance with partners' reports or with rates of sexually transmitted diseases). Other methodological shortcomings also may have led to overestimates of changes in risky behaviors. For example, in two of the four published studies included in a new meta-analysis,^16^ approximately 30% of patients failed to return for follow-up, and persons lost to follow-up were not considered when estimating rates of behavior changes.^79,^ ^80^ A third study reported no clear inception cohort.^81^ Most studies did not adequately report methods for ascertaining risky behaviors or state whether investigators assessing rates of risky behaviors were blinded to testing status of subjects. In addition, in the two systematic reviews that pooled data, some estimates were associated with significant heterogeneity,^17^ or heterogeneity was not reported.^16^ In addition to the fact that the studies evaluated diverse populations and counseling interventions, another factor that could explain a portion of between-study heterogeneity is that studies evaluated changes in risky behavior at different times following testing.^17^

We found no new studies comparing the efficacy of different counseling methods on risky behaviors in HIV-infected persons. However, several^66,^ ^82^–^84^ trials reviewed in the 2005 evidence synthesis found targeted counseling (tailored to participants) or more intensive counseling associated with greater reductions in risky behaviors than standard or less intensive counseling.

## Have Self-reported Reductions in Risky Behaviors Been Shown to Reduce Spread of Disease?

Using a mathematical formula, one new study using data from a new meta-analysis (reviewed above^16^) calculated an HIV transmission risk 3.5 times lower in HIV-positive patients aware of their status (6.9%) compared to those unaware (2.0%).^22^ It estimated a 31% decline in new sexual infections per year (from 32,000 to 22,150) if all HIV-positive patients unaware of their status became aware. However, the reliability of these estimates is uncertain because studies included in the meta-analysis relied on self-reported behavior changes and had methodological flaws (such as attrition bias, lack of clearly defined inception cohorts, and unclear blinding of outcome assessors). Even if estimates of decreased risky behaviors are accurate, rates of HIV transmission are affected by a variety of factors (such as type of risky behaviors, number of risky behavior episodes, number of sexual partners, viral load, use of antiretroviral therapy, presence of other sexually transmitted diseases, CD4 count, and time since diagnosis),^85^ many of which are not captured in the formula used in this study. The estimate of reductions in the number of new sexual infections also assumes that all patients who are HIV-positive will be tested and reduce behaviors accordingly. However, patients who are at highest risk for transmitting infection may not be equally likely to be tested or reduce risky behaviors compared to those at lower risk for transmitting infection. The formula also does not consider potential effects of testing in those with negative results, who had higher rates of subsequent STD's in some studies.^64,^ ^65^

We identified no other new studies evaluating the association between changes in risky behaviors in HIV-positive persons and reduced risk of horizontal transmission. A systematic review included in the 2005 evidence synthesis found that consistent use of condoms, defined as use of a condom for all acts of penetrative vaginal intercourse, resulted in an 80% reduction in heterosexual transmission of HIV.^86^ Another pooled analysis found condoms 90% to 95% effective when used consistently, and consistent condom users 10 to 20 times less likely to become infected when exposed to the virus than inconsistent or non-users.^87^

## What Is the Cost-Effectiveness of Screening for HIV Infection in the General Population?

We identified no new cost-effectiveness analyses of HIV screening in the general population. In two good-quality studies included in the 2005 evidence synthesis, the cost-effectiveness of one-time HIV screening compared to no screening in outpatients with 1% prevalence of unidentified HIV infection was $38,000 to $42,000 per quality-adjusted life-year gained, when secondary transmission benefits were not included.^55,^ ^56^ Neither study included long-term cardiovascular harms associated with HAART when calculating cost-effectiveness.^88^ In one of the studies, cost remained <$50,000 per quality-adjusted life-year at a prevalence of 0.5%.^55^ After incorporating estimates of beneficial effects on secondary transmission, cost-effectiveness remained less than $50,000 per quality-adjusted life-year at HIV prevalences substantially lower than seen in the general population (0.05%).^55^ The other study, which did not directly incorporate secondary transmission benefits into its model, estimated an incremental cost-effectiveness of one-time screening in the general population (prevalence of unknown HIV infection 0.1%, corresponding to an overall HIV prevalence of about 0.4%) greater than $100,000 per quality-adjusted life-year.^56^

Neither cost-effectiveness analysis evaluated incremental cost-effectiveness ratios of a strategy of screening only persons reporting risk factors, as suggested by the 2005 USPSTF recommendations, compared with a strategy of universal screening in low-prevalence settings. In addition, in the study that included secondary transmission benefits, cost-effectiveness in low-prevalence settings was sensitive to estimates of beneficial effects of screening on transmission.^55^ The other cost-effectiveness analysis did not directly incorporate secondary transmission benefits, but estimated that screening 100,000 persons in the general population would prevent 10 of the 780 to 1,060 expected secondary transmissions.^56^ A subsequent analysis based on the model used in the latter study found that increasing rates of test notification and entry into care had a greater impact on cost-effectiveness than similar increases in rates of testing.^23^