# Introduction

This report updates an evidence synthesis commissioned by the U.S. Preventive Services Task Force (USPSTF) and completed in March 2005,^1^ on screening for unsuspected human immunodeficiency virus (HIV) using HIV antibody (Ab) tests in non-pregnant adolescents (aged 13 to 18 years old) and adults. This brief update was requested by the USPSTF to determine whether there is sufficient new evidence to justify revision of recommendations based on the 2005 evidence synthesis.^2^ A key reason for this update is the release in September 2006 of revised Centers for Disease Control and Prevention (CDC) recommendations advising routine voluntary HIV screening of most U.S. adolescents and adults.^3^ The 2005 USPSTF recommendations differ from the revised CDC recommendations in that they do not recommend for or against routine screening non-pregnant adults and adolescents who do not report risk factors and are not in high-prevalence (>1%) or other high-risk settings.^2^ Staff at the CDC have indicated that the agency's expanded screening recommendations are based primarily on new evidence as to the effects of HIV screening on transmission risk. This report focuses on new or “breakthrough” evidence that could affect the 2005 USPSTF recommendations regarding routine screening of low- or average-risk adults and adolescents.

## Burden of Condition / Epidemiology

It is estimated that approximately one million persons in the United States are infected with HIV, and approximately 400,000 persons are known to be living with the acquired immunodeficiency syndrome (AIDS) in 2003.^4^ Of those infected, 25% (180,000–280,000) are thought to be unaware of their positive status.^4,^ ^5^ New surveillance data from the CDC indicates no significant changes in the number of new HIV or AIDS diagnoses between 2001 and 2004.^6^ Rates of infection remain highest among non-Hispanic blacks (8.4 times higher than among whites).^7^

## Healthcare Interventions

There remains no effective vaccine to prevent HIV infection and no cure for chronic infection. Of the interventions used to treat chronic HIV infection, highly active antiretroviral therapy (HAART) has the greatest impact on clinical outcomes, including survival.^8^ Since the USPSTF evidence synthesis was completed in 2005, updated guidelines for antiretroviral therapy have been published.^9,^ ^10^

## Prior Recommendations

The USPSTF released updated recommendations for HIV screening in 2005.^2^ The USPSTF recommends screening all patients at higher risk for HIV infection (including those reporting risk factors and those in high-prevalence or high-risk clinical settings) and all pregnant women (A recommendations).^2^ The USPSTF makes no recommendation for or against routinely screening for HIV non-pregnant adults and adolescents not at higher risk for HIV infection. Although it found fair evidence that screening adolescents and adults not known to be at increased risk for HIV can detect additional individuals with HIV, and good evidence that appropriately timed interventions lead to improved health outcomes for some of those individuals, the USPSTF concluded that the yield from screening persons without risk factors in low-prevalence settings would be low, and that there may be potential harms^1^ of screening as well as additional burdens on clinicians. The USPSTF concluded that the benefits are too small relative to potential harms to justify a general recommendation for routine screening (C recommendation). The USPSTF made no recommendations on the frequency of screening or on methods of pre-test counseling.

The 2005 USPSTF recommendations are generally consistent with the 2001 CDC recommendations, which defined high prevalence of HIV infection as >1%, or an AIDS diagnosis rate of >1 per 1000 hospital discharges.^11^ These thresholds were based on prevalence data from 1993. High-risk clinical settings as defined by the 2001 CDC recommendations are shown in Table 1.

Table 1 2001 CDC Recommendations for Counseling and Testing for HIV Infection*

Recommended screening | Examples
All clients in settings serving populations at increased behavioral or clinical HIV risk (regardless of setting HIV prevalence) | Adolescent or school-based health clinics with high rates of sexually transmitted diseases
| Clinics serving men who have sex with men
| Correctional facilities, prisons, juvenile detention centers
| Drug or alcohol prevention and treatment programs
| Freestanding HIV test sites
| Homeless shelters
| Outreach programs (e.g., syringe exchange programs)
| Sexually transmitted diseases clinics
| Tuberculosis clinics (only persons with confirmed or suspected tuberculosis and their contacts)
Individual clients in setting with <1% HIV prevalence who have:; - Clinical signs or symptoms suggesting HIV infection; - Diseases suggesting increased risk for HIV infection; - Self-report HIV risks; - Specifically request an HIV test | Fever or illness of unknown origin
| Opportunistic infection (including active tuberculosis disease) without known reason for immune suppression
| Another sexually transmitted disease or bloodborne infection
| Injection drug use with shared injection equipment (e.g., needles, syringes, cotton, water)
| Unprotected intercourse with someone suspected of being infected (partner injects drugs, diagnosed or treated for a sexually transmitted disease or hepatitis, has had multiple or anonymous sex partners, or has exchanged sex for drugs or money)
| Unprotected vaginal or anal intercourse with more than one sex partner
| Diagnosed or treated for a sexually transmitted disease, hepatitis, or tuberculosis
All clients in settings with a ≥ 1% HIV prevalence | Specific inpatient and outpatient settings with known high prevalence
Regardless of setting prevalence or behavioral or clinical risk:; - All pregnant women; - All clients with possible acute occupational exposure; - All clients with known sexual or needle-sharing exposure to an HIV-infected person

* Source: Centers for Disease Control and Prevention. Revised guidelines for HIV counseling, testing, and referral. MMWR. 2001;50(RR-19):1–57.^11^

The revised 2006 CDC recommendations advise routine voluntary screening for all persons aged 13 to 64 years through opt-out testing (notifying patients that testing will be performed unless they decline), unless prevalence of undiagnosed HIV infection is documented to be <0.1% and no risk factors are identified.^3^ The CDC also recommends screening all patients initiating treatment for tuberculosis and those seeking treatment for STDs (including all patients attending STD clinics) at each visit for a new complaint. The CDC recommends testing all persons likely to be at high risk for HIV infection at least annually and encourages testing of patients and prospective partners before initiating a new sexual relationship, but does not provide specific guidance for repeat screening in average or low-risk persons. The 2006 CDC recommendations also differ from previous CDC recommendations in that they advocate more streamlined HIV testing procedures and do not require separate written consent for HIV screening or prevention counseling as part of testing. These changes are intended to help reduce barriers to testing, decrease burdens associated with pre-test counseling, and increase acceptability of screening by patients and clinicians.

## Scope of Update

This update reviews new evidence on HIV screening not included in the 2005 evidence synthesis. It focuses on evidence in non-pregnant, adults and adolescents who do not report risk factors and are evaluated in lower-prevalence (<1%), low-risk clinical settings (referred to in this report as ‘low-risk’ persons), because this is the population for which the USPSTF and the 2006 CDC recommendations are discordant. In the 2005 evidence review, we identified several key areas where additional evidence could strengthen the case for screening in low-risk populations.^1^ These include gaps in the research regarding uncertainties about the acceptability of routine voluntary screening in low-risk persons; the yield of targeted versus universal screening and optimal methods of risk assessment in low-risk settings; the impact on test uptake and follow-up of abbreviated or streamlined counseling methods and newer testing or sampling methods; and the effects of screening on HIV transmission rates. We therefore focused on studies that could help fill in these gaps. We also evaluated new evidence on the cost-effectiveness of routine HIV screening and studies on the frequency of testing.