# Appendixes

Appendix 1. Search strategies

Appendix 2. Study Selection—Screening Forms

Appendix 3. Quality Rating Criteria

Appendix 4. Detailed Report Supporting Sections

Appendix 5. Results: Harms Due to COX-2 Inhibitor Use (Including COX-2 Selective)

Appendix 6. Results: The Impact of NSAID Chemoprevention on FOBT Testing

Appendix 7. QUOROM flowchart

Appendix 8. Figures and Tables