# Appendix 8. Figures and Tables

## Figures

Figure 1. Decision making hierarchy for grouping of included studies

Figure 2.1. Incidence of colorectal cancer

NOTE: There were also two cohort studies on CRC mortality in average-risk subjects{56}{155}

Figure 2.2. Incidence of colonic adenomas

Any=Any NSAID

## Evidence Tables

Evidence Table 1.1. ASA-NSAIDs and CRC/adenoma: Incidence—Randomized Controlled Trials

Author, Year, Location, | N | Duration | Population | Intervention | Outcomes assessed | Quality
Baron, 2003, US ^18^ | 1,121/1,084 | 7 y | Inclusion criteria: | ASA 81mg/d vs. ASA 325mg vs. placebo | Primary: | Good
| | | Healthy 21–80 y old; with 1 or + histologically confirmed CRA removed within 3 mo, or within 16 mo with hx of two or more confirmed CRA, or a histologically confirmed adenoma ≥ 1 cm in diam. removed within 16 mo; complete CC within 3 mo with no colorectal polyps remaining | | -% of pts with 1 or > adenomatous polyp 1 y post randomization or later
| | | Exclusion criteria: | | Secondary:
| | | Hx of familial CRC syndrome; invasive large-bowel cancer; malabsorption syndromes; CI to aspirin, NSAIDS, or folate | | -n of adenomatous or more advanced lesions
| | | | | -n of right-sided vs. left-sided lesions
Benamouzig, 2003, France ^19^ | 272/238 | > 8 y | Inclusion criteria: | Lysine acetylsalicylate (Sanofi-Synthelabo) 160mg/d (n=73) vs. 300mg/d (n= 67) vs. placebo | Primary: | Good
| | | Pts 18–75 y, with ≥ 3 CRA of any size, or 1 ≥6 mm; no regular use of ASA or other NSAIDs (7 consecutive d >3 wk/y or > 21 d/y); removed polyps < 3 mo upon consultation; with a clean colon/ rectum at entry; eligible women: menopausal or with efficient contraception | | -Recurrence of adenoma at 1y & 4 y (NR)
| | | Exclusion criteria: | | Secondary:
| | | Hx of CRC; FAP, bowel resection excluding appendectomy, IBD, or debilitating or life threatening dx | | -Toxicity & tolerability of ASA (NR)
Gann, 1993, US ^20^ | 22071/NR | 6 y | Inclusion criteria: | ASA vs. placebo | Primary: | Fair
| | | US male physicians, age 40–84 y | | -OR CRC
| | | Exclusion criteria: | | Secondary:
| | | hx of CVD, cancer, liver or renal disease, gout, peptic ulcer, CI to ASA, or current use of NSAIDs or vitamin A | | -OR polyps
Ladenheim, 1995, US ^21^ | 44/40 | 4 mo | Inclusion criteria: | Sulindac for 4 mo (n= 22) vs. placebo | Primary: | Fair
| | | Adults > 50 y, with routine screening flexible sigmoidoscopy, polyps ≤ 1 cm | | -Polyp disappeared or regressed (>2 mm reduction in size)
| | | Exclusion criteria:
| | | Hx of GI bleeding, CRF, PUD, underlying malignancy, long-term over-the-counter or prescription NSAIDs use (except ASA); decompensated pulmonary or cardiac disease; polyp(s) > 1 cm

N = number of participants enrolled/completed; y = year(s); mo = month(s); wks = week(s); d = day(s); CI = contraindication; CRC = colorectal cancer; CRA = colorectal adenoma; NSAID = no steroid anti-inflammatory drugs; FAP = familial adenomatous polyposis; IBD = inflammatory bowel disease; CRF = chronic renal failure; CVD = cardiovascular disease; GI = gastrointestinal; ASA = acetylsalicylic acid; PUD = peptic ulcer disease

Evidence Table 1.2. ASA-NSAID and adenomas/CRC: Incidence and Mortality—Cohort studies

Author, Year, Location, | N | Study Duration | Population | Exposure(s) | Outcomes assessed | USPSTF Quality Rating
Chan, 2004, US ^14^ | 27,077/27,077 | 21 y | Inclusion criteria: | ASA: 0.5–1.5 tabs/wk (n=6,340); | Primary: | Good
| | | Women (registered US nurses), age 30–55 y, who completed baseline dietary questionnaire, & underwent CC or sigmoidoscopy during study period | ASA: 2–5 tabs/wk (n=4,172); | -Incidence of adenoma: (RR)
| | | Exclusion criteria: | ASA: 6–14 tabs/wk (n=4,352); | Secondary:
| | | Incomplete questionnaires; no data/implausible dietary/ASA data; hx of cancer (except nonmelanoma skin cancer), CRA, IBD, or FAP | ASA: >14 tabs/wk (n=1,634); | -Proximal adenomas in absence of distal synchronous adenoma (RR)
| | | | -non exposed: (n=10,579);
Friis, 2003, Denmark ^38^ | 29,470/29,470 | 9 y | Inclusion criteria: | Low-dose ASA (follow up: 6 y) (n=29,470) | Primary: | Fair
| | | Pts with prescribed low-dose ASA max doses of 150 mg, Danish Cancer registry, controlled for age, gender, county | | -Incidence all cancers
| | | Exclusion criteria:
| | | Residency outside country of North Jutland; invalid civil registry number; death prior to/at date of prescription; parent (of patient) registered as customer.
Giovannucci, 1995, US ^33^ | 89,446/85,868 | 12 y | Inclusion criteria: | ASA use in all 3 questionnaires (n=95,258 PYs); | Primary: | Good
| | | Female nurses who completed the sections on medication use & food-frequency questionnaire in 1980 | nonexposed (n=456,393 PYs) | -Incidence of CRC
| | | Exclusion criteria:
| | | Hx of cancer (excluding nonmelanoma skin cancer), FAP, or ulcerative colitis
Giovannucci, 1994, US ^15^ | 47,900/45,505 | 7 y | Inclusion criteria: | ASA: in all 3 questionnaires (n=11,260 Pys) in CRC study; | Primary: | Good
| | | Male health professionals respondents to mailed questionnaire in 1986, age 40–75 y | ASA: in 1986 survey only (n=1,242); | -Incidence of CRC (RR)
| | | Exclusion criteria: | Non-exposed: (n=30,020 PYs in CRC study); | Secondary:
| | | NR | non-exposed: (n= 2,472 in adenoma study) | -Distal adenomatous polyp (RR)
Greenberg, 1993, US ^16^ | 864/793 | Approx. 4 y | Inclusion criteria: | ASA: consistent use (n = 102); | Primary: | Fair
| | | Pts with at least one histologically confirmed ademoma removed within 3 mo pre-study entry, free of further polyps, age < 80 y, otherwise healthy | ASA: Intermittent use (n = 98); | -Incidence of adenoma (RR)
| | | Exclusion criteria: | non-exposed (n = 593)
| | | Invasive large-bowel cancer, infalammatory bowel dx, malabsorption, syndrome, or any contraindication to betacarotene, vitamin C, E (hx of kidney stones or thrombophlebitis)
Lipworth, 2004, Denmark ^36^ | 113,538/102,566 | 7 y | Inclusion criteria: | Ibuprofen (n=113,538) | Primary: | Fair
| | | Pts with at least 1 ibuprofen prescription between 1989–1995 | | -Overall mortality
| | | Exclusion criteria: | | Secondary:
| | | NR | | -Mortality from GI bleeding, CVD & cancer
Paganini-Hill, 1995, USA ^40^ | 13979 /12180 | 11 y | Inclusion criteria | ASA: <daily; ASA: daily | Primary: | Poor
| | | Community residents with returned questionnaire on medical hx, use of drugs, laxatives & supplements, smoking, alcohol consumption, & exercise habits, health care utilization, & females: menstrual hx, i.e. estrogen tx | | -n of CRC
| | | Exclusion criteria:
| | | NR
Schreinemachers, 1994, US ^34^ | 14,407/12,668 | 16 y | Inclusion criteria: | ASA: within 30 d of baseline interview (n=7438); | Primary: | Fair
| | | Pts with medical examination & were 25–74 y at the time of NHANES I (National Health & Nutrition Examination Survey I) | Non-ASA: within 30 d of baseline interview (n=5250) | -Incidence of all cancers
| | | Exclusion criteria:
| | | Cases: dx occuring =/> 2 y NHANES I; Ctrls: incomplete surverys/aspirin use data
Smalley, 1999, US ^39^ | 104217/NR | 13 y | Inclusion criteria: | non-ASA NSAID cumulative dose <3 mo (n = 93,392 Pys); 3–11 mo (n = 82,247 Pys); 12–23 mo (n = 47,326 Pys); 24–35 mo (n = 24,919 Pys); 36–47 mo (n = 22,450 Pys); <48 mo (n = 9,962 Pys); | Primary: | Fair
| | | Enrollees of the Tennessee Medicaid program, 65 y or older, with 5 or more y continuous enrollment (5 y medical hx available) | non-exposed (n = 166,769 Pys) | -Incidence of CRC
| | | Exclusion criteria:
| | | End point: dx with incident colorectal cancer, death, loss of eligibility, or the end of the study (Dec 1992)
Sorensen, 2003, Denmark & US/Sweden ^37^ | 183693/172057 | 9 y | Inclusion criteria: | ASA: 1 prescription (n=71603); 2–4 prescriptions (n=59964); 5–9 prescriptions (n=21398); ≥ 10 prescriptions (n=19092) | Primary: | Fair
| | | Pts with prescribed non-aspirin NSAIDs | | -incidence of CRC
| | | Exclusion criteria:
| | | Occurence of cancer excluding nonmelanoma skin cancer proir to the date of first recorded perscription; end of follow-up: cancer dx, death, emigration or reaching study end date (Dec 1, 1997)
Sturmer, 1998, US ^32^ | 22071/22071 | 12 y (RCT X 5 y; cohort X 7 y) | Inclusion criteria: | Randomized to ASA/ regular ASA use thereafter (n = 41869 PYs); | Primary: | Poor
| | | US male physicians, 40–84 y in 1982 | Randomized to Placebo/ irregular ASA use thereafter (n = 18342 PYs) | -RR CRC
| | | Exclusion criteria:
| | | Regular use of aspirin or other NSAIDs; hx of myocardial infarction, stroke, cancer, liver or renal dx, gout, peptic ulcer, or contraindications to aspirin
Tangrea, 2003, US ^17^ | NR/1905 | 4 y | Inclusion criteria: | ASA:, any use (n = 431); up to 325mg/day (n = 369); >325mg/day (n = 62); unexposed (n =1474); | Primary: | Good
| | | Enrolees of the Polyp Preventin Trial, 1991, at least 35 y old with one or more histologically confirmed colorectal adenomas identified by complete colonoscopy within 6 mo prior to randomization. | NSAID: any use (n = 629); unexposed (n = 1276); | -n of polyps
| | | Exclusion criteria: | Use reported at all 5 visits (n = 253); no use reported at all 5 visits (n =1462)
| | | Hx of colorectal cancer, surgical resection of adenomas, inflammatory bowel syndrome, or the familial polyposis syndrome
Thun, 1991, US ^35^ | 1083531/662424 | 6y | Inclusion criteria: | ASA: <1 a mo (n = 486,620 PYs men & n = 671,927 PYs women); 1–15 times a mo (389,083 PYs men & 505,854 PYs women); ≥ 16 times a mo (n = 201,638 PYs men & n = 265,424 PYs women); | Primary: | Fair
| | | White adults (friends/family of volunteers for Cancer Prevention Study II in 1982) who provided information in 1982 on the frequency & duration of aspirin use | non-exposed: (n = 646,346 PYs men & n = 705,064 women) | -Mortality from CRC
| | | Exclusion criteria:
| | | Non-white (due to small # of death in this grp); aspirin use < 1 y

N = number of participants enrolled/completed; y = year(s); mo = month(s); wk = week(s); d = day(s); n = number; pts = patients; hx = history; dx = diagnosis; tx = treatment; NR = not reported; CRC = colorectal cancer; CRA = colorectal adenoma; NSAID = non steroid anti-inflammatory drug; FAP = familial adenomatous polyposis; IBD = inflammatory bowel disease; CRF = chronic renal failure; ASA = acetysalicylic acid; RR = relative risk; PYs = person-years; GP = general practitioner; CC = colonscopy;

Evidence Table 1.3. ASA-NSAID and adenomas/CRC: Incidence and Mortality—Case-Control Studies

Author, Year, Location | N | Duration | Cases | Controls | Exposure (Ascertainment) | Outcomes assessed | USPTF Quality Rating
Bigler, 2001, US ^1^ | 1037/1037 | 3y | Cases: incident of adenomatous polyp (n = 474) | Controls: colonoscopy negatives (n = 563) | ASA; non-ASA NSAID (questionnaire) | Primary: | Fair
| | | | | | -n of polyps
Hauret, 2004, US ^5,^ ^13^ | 669/405 | 2 y | Cases: colonoscopy positives (n = 177) | Controls: Subjects free of adenomas (n = 228) | Non-ASA NSAID (questionnaire) | Primary: | Poor
| | | | | | -n of polyps
Breuer-Katschinski, 2000, Germany ^9^ | 1265/550 | 3.5 y | Cases: pts with histoligically proven & endoscopy removed adenoma of colon or rectum (n = 182); | Hospital Controls: matched for age & sex free of adenomatous polyps at colonoscopy (n = 178); | NSAID (questionnaire) | Primary: | Fair
| | | | Non-hospital (community) Controls: selected pts of the same age and sex from the inhabitants list of the City of Essen (n = 182); | | -n of polyps
Collet, 1999, Canada ^29^ | Colon Cancer Study NR/19217 | NR | Cases: pts with histologically proven adenocarcinoma of colon or rectum & reported to SCA (n = 3844 colon; n = 1971 rectal) | Controls: matched in age, gender with cases, and alive, > 35 y at entry; free of CRC & other cancer except non-melanoma & carcinoma in situ of cervix (n = 15,373 matched to colon cancer cases; n = 7,882 matched to rectal cancer cases) | NSAID (prescription drug database) | Primary: | Good
| Rectal Cancer Study NR/9853 | | | | | -n of CRC
Coogan, 2000, US ^28,^ ^41,^ ^42^ | 11754/11754 | 13 y | Cases: primary CRC (n = 1032 colon; n = 494 rectum) dx < 6 mo | Cancer Controls: dx of lung, or other respiratory, malignant melanoma, prostate bladder, kidney, ovary, uterus, and other cancers dx < 6 mo (n = 4192) | NSAID (tumor registry of hospitals; Sate Cancer registry) | Primary: | Fair
| | | | Non-Cancer Controls: pts admitted for trauma, or acute infection with no hx of cancer (n = 6036) | | -n of CRC
Garcia Rodriguez, 2000, Spain ^8,^ ^22^ | 943903/NR | 5 y, 8 mo | Adenoma Cases: adenoma on medical records database with biopsy (n = 1864); | Controls: randomly selected age, sex matched persons from database; absence of adenoma (n = 10,000) | Non-ASA NSAID, ASA, Ibuprofen, Diclofenac, Naproxen, Indomethacin, Piroxicam, Ketoprofen (prescription database) | Primary: | Good
| | | CRC Cases: incident of CRC (n = 2002) | | | -n of polyps
| | | | | | -Incidence of CRC (by sex & age-groups)
Juarranz, 2002, Spain ^27^ | 502/424 | NR | Cases: subjects with laboratory-confirmed colon cancer between January 1995 – December 1996, residing in Madrid (n=196) | Controls: subjects free of neoplasm or severe digestive disease (Crohn's or ulcerative colitis) at enrollment, randomly chosen, from electoral lists from same area as cases & age-sex matched to cases | ASA & NSAIDs (questionnaire) | Primary: | Fair
| | | | | | -n of colon cancer cases
Kahn, 1998, US ^10^ | 177939/154224 | 10 y | Cases: self reported polyps on mailed questionnaire (n = 7504 men; n = 5111 women) | Controls: subjects who did not report the polyp (n = 65,364 men; n = 76,245 women) | ASA (questionnaire) | Primary: | Poor
| | | | | | -n of polyps
Kune, 1988, Australia ^25^ | 1442/1367 | 1 y | Cases: newly dx CRC between Apr 1980–Apr 1981(n = 715) | Controls: randomly selected pts matched for age, sex, & geographic area | ASA, NSAID (questionnaire) | Primary: | Fair
| | | | | | -RR CRC, RR colon cancer, RR rectal cancer
La Vecchia, 1997, Italy ^23^ | 3248/3248 | 4.5 y | Cases: histologically confirmed CRC (n = 860 colon; n = 497 rectum) | Controls: pts in the same residing area/hospital of cases, identified for acute conditions unrelated to known or likely risk factors for CRC (n = 1891) | ASA (questionnaire) | Primary: | Fair
| | | | | | -OR CRC
Lieberman, 2003, US ^6^ | 3121/1770 | 3 y | Cases: advanced neoplasia ≥ 10mm; villous adenoma at least 25% villous; high grade dysplasia included carcinoma in situ & intramucosal cancer; invasive cancer (malignant cells beyond muscularis mucosa) (n = 329) | Controls: Pts free of lower tract GI symptoms & polyps (n = 1441) | NSAID (questionnaire) | Primary: | Fair
| | | | | | -n of polyps
| | | | | | -n of CRC
Logan, 1993, United Kingdom ^3^ | 476/NR | 7 y | Cases: pts with positive results in faecal occult blood tests with CRA (n = 147) | Contols: matched for age & sex; pts tested negative on occult blood test (negative controls), and pts with positive results on screening but found to be free of adenomas and carcinomas or sigmoidoscopy and barium enema (positive controls) (n = 153) | ASA, NSAIDS, non-ASA NSAIDS (questionnaire) | Primary: | Fair
| | | | | | -n of polyps
Martin, 2002, US ^7^ | 719/504 | 2 y | Cases: First incident of adenoma (n = 226) | Controls: free of adenomatous polyps (n = 493) | NSAIDS (questionnaire) | Primary: | Good
| | | | | | -OR adenoma
Martinez, 1995, US ^2^ | 919/637 | Approx. 19 mo | Cases: first pathological dx of villous, tubular or tubulovillous adenomatous polyps (adenomas and hyperplastic polyps were both included) (n = 157) | Controls: negative for colorectal polyps (n = 480) | NSAID (questionnaire) | Primary: | Good
| | | | | | -OR adenoma
Muscat, 1994, US ^24^ | 1011/1011 | 3 y | Cases: histologically confirmed colorectal cancer pts (n = 346 colon; n = 165 rectum) | Controls: matched pts by sex, race, hospital, age (+/-5 y), & mo of interview; conditions unrelated to NSAID use (n = 500) | NSAID (questionnaire) | Primary: | Poor
| | | | | | -OR CRC
Peleg, 1996, US ^12^ | Study 1: 279/279 | Study 1: 5.5 y | Study 1: Cases: incident CRC (n = 93) | Controls: hospital pt free of cancer, born 1948, with regular follow ups at GMH for the same duration as the case at the time | NSAID (prescription database) | Primary: | Poor
| Study 2: 339/339 | Study 2: 2.5 y | Study 2: Cases: incident adenoma (n = 113) | Study 1: (n = 186); | | -n of CRC
| | | | Study 2: (n = 226) | | Secondary:
| | | | | | -n of polyps
Reeves, 1996, US ^30^ | 845/400 | 1 y | Cases: women 40–74 y, local residents with new dx of invasive cancer of the colon or rectum, with listed telephone number (n = 184) | Controls: pts with listed telephone number, & either a current Wisconsin driver's license (< 65 y), or a Medicare card (>65 y) (n = 293) | ASA, NSAID, non-ASA NSAID (questionnaire) | Primary: | Fair
| | | | | | -n of CRC
Sandler, 1998, US ^11^ | 492/379 | 3 y | Cases: incident of adenoma (n = 142) | Controls: free of adenomatous polyps or having hyperplastic (n = 169) | ASA, NSAID, non-ASA NSAID (questionnaire) | Primary: | Fair
| | | | | | -n of polyps
Shaheen, 2003, US ^26^ | 1308/ 1308 | 4 y | Cases: pts 40–79 y; residing in 33-county area, with first time dx of colon cancer (enrolled within 22–63 d, median 34 d from dx date) between Oct. 1996–Oct. 2000 (n = 475) | Controls: sampled from same geographic area age > 65 y; & driver's licence age < 65 y (n = 833) | NSAID (questionnaire) | Primary: | Fair
| | | | | | -OR CRC
Slattery, 2004, US ^31^ | 3051/2157 | 5 y, 2 mo | Cases: English speaking, mentally competent to complete the interview, 30–79 y; first primary tumor in the rectosigmoid junction or rectum, May 1997–May 2001 (n = 952) | Controls: matched by sex & by 5-y age group, pts> 65 randomly selected from Health Care Financing Administration lists, pts < 65 y selected from driver's license lists (n = 1205) | ASA, NSAID (questionnaire) | Primary: | Fair
| | | | | | -n of CRC
Suh, 1993, US ^4^ | 2704/NR | 9 y | Cases 1: first primary colon cancers (n = 490) | Controls 1: Prevention health care healthy visitors (n = 1138) | ASA (questionnaire) | Primary: | Fair
| | | Cases 2: first primary rectum cancers (n = 340) | Controls 2: healthy pts without cancer (n = 524) | | -n of polyps
| | | | | | -n of CRC

N = number of participants enrolled/completed; y = year(s); mo = month(s); wk = week(s); d = day(s); n = number; pts = patients; hx = history; dx = diagnosis; NR = not reported; CRC = colorectal cancer; CRA = colorectal adenoma; NSAID = non steroid anti-inflammatory drug; ASA = acetysalicylic acid; RR = relative risk; OR = odds ratio; GMH = Grand Memorial Hospital; SCA: Saskatchewan Cancer Agency

Evidence Table 2.1. RCTs

Author, Year, Location | Population Risk | Experimental Intervention (dose & duration) | Sample Size (n experimental arm/n control arm) | OR (95% CI)*
RCTs of incidence of CRC with aspirin use
Gann, 1993, U.S. ^20^ | Average | 325 mg every other d for 5 y | 11,037/11,034 | 1.15 (0.80, 1.65)
RCTs of incidence of adenomas with aspirin use
Gann, 1993, U.S. ^20^ | Average | 325 mg every other d for 5 y | 11,037/11,034 | 0.86 (0.68, 1.1)
Benamouzig, 2003, U.S., France ^19^ | Higher | 160 mg/d for 4 y | 73/132 | 0.85 (0.57, 1.26)
| | 300 mg/d for 4 y | 67/132 | 0.61 (0.37, 0.99)
Baron, 2003, U.S. ^18^ | Higher | 81 mg/d for 3 y | 377/372 | 0.81 (0.69, 0.96)
| | 325 mg/d for 3 y | 372/372 | 0.96 (0.81, 1.13)
RCTs of incidence of adenomas with non-aspirin NSAIDs use
Ladenheim, 1995, U.S. ^21^ | Higher | Sulindac 300 mg/d for 4 mo | 22/22 | 1.65 (NS; 95% CI = NR)

* Reference group = placebo arm; RR = relative risk; CI = confidence interval; y = year(s); n = number; RCT = randomized controlled trial; CRC = colorectal cancer; d = day(s); NS = not significant; NR = not reported; mo = month(s); n = number; NSAID = non-steroidal anti-inflammatory drug

Evidence Table 2.2. Cohort Studies

Author, Year, Location | Population Risk | Exposure Group(s) (duration, dose, recency, & regular use) | Sample Size (n exposed/n non-exposed) | OR (95% CI)
Cohort studies of incidence or mortality of CRC with aspirin use
Sturmer, 1998, U.S. ^32^ | Average | ≥ 1 y | 34,983 p-y/18,342 p-y | 1.02 (0.64, 1.65)
| | ≥ 5 y | 11,563 p-y/18,342 p-y | 0.95 (0.51, 1.79)
| | ≥ 6 y | 41,869 p-y/18,342 p-y | 1.07 (0.67, 1.70)
| | regular use | 41,869 p-y/18,342 p-y | 1.07 (0.67, 1.70)
Giovannucci, 1995, U.S. ^33^ | Average | 1 – 4 y | 70,860 p-y/357,905 p-y | 1.06 (0.78, 1.45)
| | 5 – 9 y | 42,306 p-y/357,905 p-y | 0.84 (0.55, 1.28)
| | 10 – 19 y | 28,709 p-y/357,905 p-y | 0.70 (0.41, 1.20)
| | ≥ 20 y | 52,259 p-y/357,905 p-y | 0.56 (0.36, 0.90)
| | regular use | 95,258 p-y/456,393 p-y | 0.62 (0.44, 0.86)
Giovannucci, 1994, U.S. ^15^ | Average | ≥ 2 y | 33,661 p-y/75,637 p-y | 0.54 (0.34, 0.83)
| | ≥ 4 y | 11,260 p-y/30,020 p-y | 0.35 (0.16, 0.75)
| | regular use | 33,661 p-y/75,637 p-y | 0.54 (0.34, 0.83)
Friis, 2003, Denmark, U.S. ^38^ | Average | 1 – 4 y | NR/NA | SIR = 1.0 (0.9, 1.2)
| | 5 – 9 y | NR/NA | SIR = 0.9 (0.7, 1.1)
| | regular use | 29,470/NA | SIR = 0.9 (0.7, 1.1)
Paganini-Hill, 1995, U.S. ^40^ | Average | regular use | Men: 4,535 (total sample) | Men: 1.38 (p ≥ 0.05)
| | | Women: 7,645 (total sample) | Women: 1.1 (p ≥ 0.05)
Schreinemachers, 1994, U.S. ^34^ | Average | regular use | Total sample: 7,438/5,250 | Total sample: 0.85 (0.63, 1.15)
| | | Men (< 65 y): NR | Men (< 65 yrs): 0.36 (0.17, 0.76)
Thun, 1991, US ^35^ | Average | regular use (16 + doses/month) | 411,188p-y/1,325,822 p-y | Colon 0.63 (0.44–0.89)
| | | | Rectum 0.79 (0.41–1.53)
Cohort studies of incidence or mortality of CRC with non-aspirin NSAIDs use
Smalley, 1999, U.S. ^39^ | Average | 1 – 2 y | 47,326 p-y/166,769 p-y | 0.65 (0.48, 0.87)
| | 4 y | 9,962 p-y/166,769 p-y | 0.49 (0.24, 1.00)
| | low dose | 9,058 p-y/164,052 p-y | 0.53 (0.26, 1.08)
| | medium dose | 68,615 p-y/164,052 p-y | 0.59 (0.45, 0.77)
| | high dose | 7,796 p-y/164,052 p-y | 0.77 (0.41, 1.45)
| | recency of use (< 1 y before Dx) | 86,105 p-y/164,052 p-y | 0.61 (0.48, 0.77)
| | recency of use (≥ 1 y before Dx) | 18,552 p-y/164,052 p-y | 0.76 (0.50, 1.15)
| | regular use | 24,919 p-y/164,052 p-y | 0.70 (0.48, 1.02)
Sorensen, 2003, Denmark ^37^ | Average | regular use | 19,092/NA | SIR = 0.7 (0.6, 0.9)
Lipworth, 2004, Denmark ^36^ | Average | regular use | 484,369 p-y/NA | SMR colon=1.05 (0.9–1.2)
| | | | SMR rectal=1.26 (1.0–1.5)
Cohort studies of incidence of adenomas with aspirin use
Chan, 2004, U.S. ^14^ | Average | 1 – 5 y | 4,016/16,919 | 0.96 (0.80, 1.15)
| | 6 – 10 y | 2,429/16,919 | 0.90 (0.72, 1.13)
| | 11 – 20 y | 1,392/16,919 | 0.93 (0.69, 1.25)
| | >20 y | 2,321/16,919 | 0.80 (0.62, 1.02)
| | 0.5 – 1.5 tab/wk dose | 6,340/10,579 | 0.99 (0.81, 1.20)
| | 2 – 5 tab/wk dose | 4,172/10,579 | 0.86 (0.70, 1.50)
| | 6 – 14 tab/wk dose | 4,352/10,579 | 0.68 (0.55, 0.84)
| | > 14 tab/wk dose | 1,634/10,579 | 0.57 (0.42, 0.77)
| | regular use | 10,158/16,919 | 0.73 (0.61, 0.87)
Giovannucci, 1994, U.S. ^15^ | Average | regular use | 1,242/2,472 | OR = 0.65 (0.42, 1.02)
Tangrea, 2003, U.S. ^17^ | Higher | ≤ 325 mg/d dose | 369/1,474 | 0.87 (0.68, 1.11)
| | > 325 mg/d dose | 62/1,474 | 0.54 (0.30, 0.96)
| | regular use | 431/1,474 | 0.82 (0.65, 1.02)
Greenberg, 1993, U.S. ^16^ | Higher | regular use | 102/593 | 0.52 (0.31, 0.89)
Cohort studies in incidence of adenomas with any NSAIDs use
Tangrea, 2003, U.S. ^17^ | Higher | regular use | 253/1,462 | 0.64 (0.48, 0.85)

y = year(s); p-y = person-years; wk = week(s); regular use = 2–3 × per/wk for ≥ 1 y; RR = relative risk; CI = confidence interval; SIR = standardized incidence ratio; NR = not reported; NA = not applicable; CRC = colorectal cancer; NSAID = non-steroidal anti-inflammatory drug; Dx = diagnosis; tab = tablets; OR = odds ratio; d = day(s)

Evidence Table 2.3. Case–control studies

Author, Year, Location | Population Risk | Exposure Group(s) (duration, dose, recency, & regular use) | Sample Size (n cases/n controls) | OR (95% CI)
Case-control studies of incidence of CRC with aspirin use
La Vecchia, 1997, Italy ^23^ | Average | < 2 y | 1,357/1,891 | 0.9 (0.5, 1.7)
| | ≥ 2 y | | 0.6 (0.4, 1.0)
| | recency of use (< 1 y before Dx) | | 0.6 (0.4, 1.0)
| | recency of use (≥ 1 y before Dx) | | 0.9 (0.5, 1.6)
| | regular use | | 0.7 (0.5, 1.0)
Slattery, 2004, U.S. ^31^ | Average | ≥ 1 mo (current) | 952/1,205 | 0.8 (0.6, 1.0)
| | regular use | | 0.8 (0.5, 1.2)
Friedman, 1998, U.S. ^43^ | Average | 1 - ≤ 5 y | 1,993/2,410 | 0.8 (0.6, 1.0)
| | >5 y | | 0.8 (0.6, 0.9)
| | recency of use (< 1 y before Dx) | | 0.6 (0.5, 0.7)
| | recency of use (≥ 1 y before Dx) | | 1.0 (0.8, 1.2)
| | regular use | | 0.7 (0.6, 0.8)
Garcia-Rodriguez, 2001, Spain ^22^ | Average | 1 – 2 y | 2,002/10,000 | 0.9 (0.7, 1.2)
| | > 2 y | | 0.9 (0.7, 1.2)
| | 75 mg dose | | 1.1 (0.8, 1.4)
| | 150 mg dose | | 1.0 (0.7, 1.4)
| | 300 mg dose | | 0.6 (0.4, 0.9)
| | recency of use (< 1 y before Dx) | | 1.3 (1.0, 1.8)
| | recency of use (≥ 1 y before Dx) | | 1.0 (0.7, 1.3)
| | regular use | | 0.9 (0.8, 1.1)
Suh, 1993, U.S. ^4^ | Average | regular use | 830/1,138 | 0.33 (0.15, 0.72)
Reeves, 1996, U.S. ^30^ | Average | regular use | 184/293 | 0.79 (0.46, 1.36)
Kune, 1988, Australia ^25^ | Average | regular use | 85/147 | 0.53 (0.40, 0.71)
Juarranz, 2002, Spain ^27^ | Average | mg/week | 196/228 | 0.98 (0.89, 0.99)
Case-control studies of incidence of CRC with non-aspirin NSAIDs use
Garcia-Rodriguez, 2001, Spain ^22^ | Average | 1 – 2 y | 2,002/10,000 | 0.4 (0.2, 0.7)
| | > 2 y | | 0.6 (0.4, 0.8)
| | low-medium dose | | 0.7 (0.5, 1.1)
| | high dose | | 0.4 (0.3, 0.7)
| | recency of use (< 1 y before Dx) | | 0.9 (0.8, 1.1)
| | recency of use (≥ 1 y before Dx) | | 1.0 (0.9, 1.1)
| | regular use | | 0.7 (0.6, 0.9)
Kune, 1988, Australia ^25^ | Average | regular use | 715/727 | 0.77 (0.60, 1.01)
Slattery, 2004, U.S. ^31^ | Average | regular use | 952/1,205 | 0.8 (0.5, 1.1)
Friedman, 1998, U.S. ^43^ | Average | regular use | 1,993/2,410 | 0.7 (0.6, 0.8)
Reeves, 1996, U.S. ^30^ | Average | regular use | 184/293 | 0.43 (0.20, 0.89)
Juarranz, 2002, Spain ^27^ | Average | mg/week | 196/228 | 0.30 (0.08, 0.98)
Case-control studies of incidence of CRC with any NSAIDs use
Peleg, 1996, U.S. ^12^ | Average | 1 y | 93/412 | 0.34 (0.12, 0.94)
| | 4 y | | 0.14 (0.02, 0.90)
| | ≥ 5 y | | 0.12 (0.04, 0.39)
| | < 320 CC dose | | 0.58 (0.26, 1.32)
| | 320 – 700 CC dose | | 0.19 (0.09, 0.52)
| | > 700 CC dose | | 0.22 (0.09, 0.56)
| | regular use | | 0.13 (0.33, 0.55)
Shaheen, 2003, U.S. ^26^ | Average | regular use | 475/833 | 0.54 (0.39, 0.75)
Coogan, 2000, U.S. ^28^ | Average | regular use | 1,211/8,535 | 1.1 (0.3, 2.3)
Muscat, 1994, U.S. ^24^ | Average | regular use | 283/276 (men) | Men
| | | 228/224 (women) | 0.64 (0.42, 0.97)
| | 1 – 4 y | | 0.77 (0.34, 1.75)
| | | | 0.93 (0.45, 1.97)
| | 5 – 9 y | | 0.47 (0.21, 0.94)
| | > 9 | | Women
| | | | 0.32 (0.18, 0.57)
| | regular use | | 0.17 (0.06, 0.49)
| | 1 – 4 y | | 0.13 (0.02, 1.39)
| | 5 – 9 y | | 0.60 (0.26, 1.36)
| | > 9
Reeves, 1996, U.S. ^30^ | Average | 0 – 2 y | 184/293 | 0.7 (0.4, 1.3)
| | 2 – 5 y | | 0.3 (0.2, 0.7)
| | > 5 y | | 1.1 (0.6, 2.0)
Collet, 1999, Canada ^29^ | Average | 0 - ≤ 0.1 mg/d dose | 3,844/15,373 | 1.01 (0.88, 1.15)
| | 0.1 < - ≤ 0.3 mg/d dose | | 0.73 (0.55, 0.96)
| | > 0.3 mg/d dose | | 0.57 (0.36, 0.89)
| | regular use | | 1.00 (0.92, 1.09)
Case-control studies of incidence of adenomas with aspirin use
Garcia-Rodriguez, 2000, Spain ^8^ | Average | 1 – 2 y | 1,864/10,000 | 0.9 (0.6, 1.3)
| | > 2 y | | 0.7 (0.5, 1.0)
| | 75 mg dose | | 0.8 (0.5, 1.1)
| | 150 mg dose | | 0.9 (0.6, 1.4)
| | 300 mg dose | | 0.6 (0.4,1.0)
| | recency of use (< 1 y before Dx) | | 1.2 (0.9, 1.7)
| | recency of use (≥ 1 y before Dx) | | 1.1 (0.8, 1.5)
| | regular use | | 0.9 (0.6, 1.3)
Morimoto, 2002, U.S. ^44^ | Average | regular use | 794/708 | 0.7 (0.5, 1.1)
Kahn, 1998, U.S. ^10^ | Average | regular use | 7,504/65,364 (men) | Men: 0.97 (0.89, 1.06)
| | | 5,111/76,245 (women) | Women: 0.85 (0.77, 0.95)
Suh, 1993, U.S. ^4^ | Average | regular use | 212/1,138 | 0.61 (0.26, 1.4)
Logan, 1993, UK ^3^ | Average | regular use | 147/153 (test-negative controls screened with occult blood test for adenomas) | 0.55 (0.3, 1.1)
Sandler, 1998, U.S. ^11^ | Average and higher | regular use | 142/169 | 0.84 (0.50, 1.43)
Breuer-Katschinski, 2000, Germany ^9^ | Higher | < 5 y | 182/182 (population-based) | 0.64 (0.26, 1.56)
| | ≥ 5 | | 0.18 (0.02, 1.63)
Case-control studies of incidence of adenomas with non-aspirin NSAIDs use
Garcia-Rodriguez, 2000, Spain ^8^ | Average | 1 – 2 y | 1,864/10,000 | 0.4 (0.2, 0.8)
| | > 2 y | | 0.7 (0.5, 1.1)
| | low-medium dose | | 0.7 (0.4, 1.3)
| | high dose | | 0.6 (0.4, 0.9)
| | recency of use (< 1 y before Dx) | | 1.2 (1.0, 1.4)
| | recency of use (≥ 1 y before Dx) | | 1.2 (1.0, 1.3)
| | regular use (Ibuprofen) | | 0.7 (0.3, 1.5)
| | regular use (Diclofenac) | | 0.6 (0.3, 1.0)
| | regular use (Indomethacin) | | 0.2 (0.1, 2.3)
| | regular use (Naproxen) | | 0.8 (0.3, 1.9)
Hauret, 2004, U.S. ^13^ | Average | regular (current) use | 177/228 | 0.62 (0.36, 1.07)
Morimoto, 2002, U.S. ^44^ | Average | regular use | 794/708 | 0.4 (0.2, 0.7)
Logan, 1993, UK ^3^ | Average | regular use | 147/153 (test-negative controls screened with occult blood test for adenomas) | 0.56 (0.30, 1.20)
Sandler, 1998, U.S. ^11^ | Average and higher | regular use | 142/169 | 0.74 (0.36, 1.51)
Breuer-Katschinski, 2000, Germany ^9^ | Higher | < 5 y | 182/182 (population-based) | 0.60 (0.18, 2.05)
| | ≥ 5 y | | 0.26 (0.03, 2.44)
Case-control studies of incidence of adenomas with any NSAIDs use
Peleg, 1996, U.S. ^12^ | Average | 1 y | 113/412 | 0.59 (0.22, 1.63)
| | 2 y | | 0.24 (0.07, 0.83)
| | 3 y | | 0.26 (0.07, 1.00)
| | 4 y | | 0.24 (0.06, 0.95)
| | ≥ 5 y | | 0.25 (0.08, 0.79)
| | < 320 CC dose | | 0.59 (0.23, 1.48)
| | 320 – 700 CC dose | | 0.56 (0.20, 1.52)
| | > 700 CC dose | | 0.31 (0.11, 0.84)
| | regular use | | 0.56 (0.20, 1.52)
Martinez, 1995, U.S. ^2^ | Average | < 5 y | 157/480 | 0.39 (0.21, 0.71)
| | ≥ 5 y | | 0.60 (0.32, 1.14)
Lieberman, 2003, U.S. ^6^ | Average | < 10 y | 329/1,441 | 0.71 (0.52, 0.96)
| | 10 – 19 y | | 0.63 (0.41, 0.99)
| | > 19 y | | 0.49 (0.30, 0.80)
| | regular use | | 0.67 (0.50, 0.89)
Martin, 2002, U.S. ^7^ | Average | regular use | 226/493 | 0.5 (0.3, 0.8)
Sandler, 1998, U.S. ^11^ | Average and higher | recency of use (≥ 1 y before Dx) | 142/169 | 0.59 (0.21, 1.67)
| | regular use | | 0.56 (0.34, 0.92)
Breuer-Katschinski, 2000, Germany ^9^ | Higher | < 5 y | 182/182 (population-based) | 0.65 (0.31, 1.34)
| | ≥ 5 y | | 0.21 (0.04, 0.99)

regular use = 2–3 × per/wk for ≥ 1 y; CI = confidence interval; y = year(s); CRC = colorectal cancer; OR = odds ratio; Dx = diagnosis; y = year(s); NSAID = non-steroidal anti-inflammatory drug; mo = month(s)

Evidence Table 3.1. Harms due to aspirin use—Systematic reviews

Author, year | N | Review characteristics/ quality | Eligibility criteria | Intervention(s) (dose range) | Results
Gibbs, 2004 ^45^ | 18,626 | Included studies | Inclusion; - Pts with previous MI; - RCTs (ASA vs. oral anticoagulation [OAD] vs. ASA + OAD or ASA + OAD vs. ASA); - Incidence of recurrent MI, all-cause mortality, & safety/harms; - ASA dose (75 – 325 mg/d); - Follow-up length: ≥ 1 y | | All-cause mortality: (1 RCT)OAD (1.2%) vs. ASA (4.5%), p<0.05
| | RCTs: n = 5 | Exclusion; - Studies involving pts who underwent CABG or PTCA without being diagnosed MI; - Abstracts | | Acute MI: (1 RCT) OAD (9.7%) vs. ASA (7.4%), p<0.001
| | e-databases
| | n = 3
| | Range years
| | 1966 - 2003
| | Quality of SR
| | Good
Hart, 2000 ^46^ | 52,251 | Included studies | Inclusion; - Subjects without clinically manifest CVD; - Major CV risk factors; - RCTs + prospective cohort studies; - Stroke incidence; - ASA vs. pb | ASA (75 to 650 mg/d) vs. pb | All-cause mortality: (5 RCTs) RR: 0.94 (0.87, 1.01), NS
| | RCTs: n = 5 | Exclusion; - >20% pts with CVD; - NR stroke outcomes | | CV -mortality: RR: 0.93 (0.83, 1.03), NS
| | Cohorts: n = 4 | | | Acute MI: RR: 0.74 [(0.68, 0.82), S
| | e-databases | | | Acute stroke: RR: 1.02 (0.86, 1.21), NS
| | n = NR
| | Range years
| | 1980 - 1998
| | Quality of SR
| | Fair
Hayden, 2002 ^47^ | 50,035 | Included studies | Inclusion; - Pts with no hx of CVD disease; - ASA vs. placebo or vs. no treatment; harms - ASA use; - MI, stroke, mortality, harms; - RCTs of at least 1 y duration; Harms - case-control, RCTs | ASA (162–500 mg/d) vs. pb | All-cause mortality: (5 RCTs) OR: 0.93 (0.84, 1.02), NS
| | RCTs: n = 5 | Exclusion; - > 10% pts with CVD | | CV-mortality: OR: 0.87 (0.70, 1.09), NS
| | e-databases | | | Acute MI: OR: 0.72 (0.60, 0.87), S
| | n = 1 | | | Acute stroke: OR: 1.02 (0.85, 1.23), NS
| | Range years | | | Hemorrhagic stroke: OR: 1.4 (0.9, 2.0), NS
| | 1966-2001 | | | Major GI bleeding: RR: 1.7 (1.4, 2.1), S
| | Quality of SR | | | GI events (total):
| | | | | 0.7/1,000 pts
| | | | | 2/1,000 pts / y in older pts
He, 1998 ^48^ | 55,462 | Included studies | Inclusion; - Human subjects; - RCTs; - No intervention difference other than ASA, intervention ≥ 1 mo | ASA (NR) vs. pb | All-cause mortality: (16 RCTs) RR: 0.85 (0.8, 0.9), S
| | RCTs: n = 16 | Exclusion; - Non-RCTs, comparison arm other than pb or no treatment, pts with acute complete stroke, study duration < 1 mo, no info on the occurrence of stroke subtypes | | CV-mortality: RR: 0.84 (0.79, 0.90), S
| | e-databases | | | Acute MI: RR: 0.68 (0.62, 0.74), S
| | n = 1 | | | All acute stroke: RR: 0.88 (0.76, 1.02), S
| | Range years | | | Hemorrhagic stroke: RR: 1.84 (1.24, 2.74), S
| | 1966 - 1997 | | | Ischemic stroke: RR: 0.82 (0.73, 0.92), S
| | Quality of SR
| | Fair
Weisman, 2002 ^49^ | 6,300 | Included studies | Inclusion; - Pts with hx of stroke/TIA, MI or angina; - RCTs | ASA (50–325 mg) vs. pb | All-cause mortality: (6 RCTs) RR: 0.82 (0.7, 0.99), S
| | RCTs: n = 6 | Exclusion; - ASA used for < 3 mo, used for nonprevention indications, coadministration with other agents, primary prevention | | Acute MI: RR: 0.7 (0.6, 0.8), S
| | e-databases | | | Acute stroke: RR: 0.8 (0.7, 1.0), NS
| | n = 3 | | | GI bleed: RR: 2.5 (1.4, 4.7)
| | Range years
| | 1970 - 2002
| | Quality of SR
| | Good
Serebruany, 2003 ^50^ | 338,191 | Included studies | Inclusion; - Risk of hemorrhagic events with antiplatelet agents; - Follow-up length: ≥ 1 mo | ASA (30 to 1.3 g/d) vs. pb | Acute stroke:
| | RCTs: n = 23 | Exclusion; - NR | | ≤ [underlined: 100 mg/d] (4 RCTs): 0.3% (0.2, 0.4)
| | e-databases | | | [underlined: 100–325 mg/d] (15 RCTs): 0.3% (0.2, 0.3)
| | n = 3 | | | ≥ [underlined: 325 mg/d]: 1.1% (0.7, 1.5)
| | Range years | | | GI bleed (%):
| | 1988 - 2002 | | | ≤ [underlined: 100 mg/d]: 1.1% (0.9, 1.3)
| | Quality of SR | | | [underlined: 100–325 mg/d]: 2.5% (2.2, 2.6)
| | Fair | | | ≥ [underlined: 325 mg/d]: 2.50% (1.8, 3.1)
Lip, 2004 ^51^ | 24,827 | Included studies | Inclusion; - RCTs; - Pts mild increases in BP or HTN; - Antiplatelet agents > 3 mo; - All-cause mortality, CV death, stroke, MI, thomboembolic events | ASA 75 mg vs. pb | Acute MI: (1 RCT) AAR: 0.5%; NNT: 200
| | RCTs: n = 5 | Exclusion; - Atrial fibrillation, CHF, preeclampsia, eclampsia, pulmonary hypertension; - Cohort, nonRCTs, open-label studies | | Ischemic stroke: (2 RCTs) OR: 0.94 (0.76, 1.17), NS
| | e-databases
| | n = 4
| | Range years
| | 1998 - 2001
| | Quality of SR
| | Good
Derry, 2000 ^52^ | 65,987 | Included studies | Inclusion; - Oral ASA as antiplatelet agent with duration ≥ 12 mo; - Trials providing numerical data on GI hemorrhage events in both ASA & pb/control arms; - RCTs | ASA (0.5–1.5 g) vs. pb | GI bleed:
| | RCTs: n = 24 | Exclusion; - Abstracts, review articles, non-randomized trials, cross-over trials, case reports, clinical observations, unpublished data, trials with < 50 pts per each arm, special populations (pregnant women, children, & pts with pre-existing platelet disorders) | | ≥[underlined: 162.5 mg/d]: RR: 1.68 (1.51, 1.88), S
| | e-databases | | | [underlined: 50–162.5 mg/d]: RR: 1.59 (1.40, 1.81), S
| | n = 3
| | Range years
| | NR
| | Quality of SR
| | Fair
Garcia Rodriguez, 2001 ^53^ | 67,722 | Included studies | Inclusion; - Adults; - ASA use vs. No ASA use; - Serious UGIC resulting in hospitalization or visit to specialist; - Case-control or cohort studies | ASA use vs. no use | GI bleed:
| | Cohorts: n= 3 | Exclusion; - No specific data on ASA or UGIC, studies reporting non-serious GI, studies combining upper & lower GI bleedings, studies with flawed methodology (selection & analysis) | | [underlined: Cohorts]: RR: 2.2 (2.1, 2.4), S
| | Case-controls: n = 14 | | | [underlined: Case-control:] RR: 3.1 (2.8, 3.3), S
| | e-databases
| | n = 1
| | Range years
| | 1990 - 2001
| | Quality of SR
| | Fair
Tramer, 2000 ^54^ | RCT: 19,364 | Included studies | Inclusion; - Gastric or duodenal ulcer, ulcer hemorrhage or perforation, death due to these events; - Oral NSAID or ASA exposure > 2 mo; - Any level of evidence | ASA (325 mg –5.2 g/d) or NSAID vs. pb | Symptomatic ulcer incidence: (RCT & cohorts) 1.48%
| Cohorts: 215,076 | RCTs = 15 | Exclusion; - Abstracts & reports of NSAID-induced complications other than Upper GI | | Bleed or perforation incidence:
| Case-control: 2,957 cases | Cohorts = 3 | | | [underlined: Low dose (325 mg q 2 d):] 0.34%
| | Case-controls = 6 | | | [underlined: 1 g/d:] 0.57%
| | e-databases | | | [underlined: 2.5 to 5.2 g/d]: 0.86%
| | n = 2
| | Range years
| | NR - 1996
| | Quality of SR
| | Fair
Roderick, 1993 ^55^ | 39,646 | Included studies | Inclusion; - GI toxicity reported in a form allowing events & symptoms to be defined in a reasonably standard manner; - ASA vs. pb; - Follow-up at least 1 y; - RCTs | ASA (0.5–1.5 g/d) vs. pb | All GI bleed: (11 RCTs)
| | RCTs = 21 | Exclusion; - NR | | OR: 2.0 (99% CI: 1.5, 2.8), S
| | e-databases | | | [underlined: 300 mg/d] (1 RCT): OR: 1.6 (0.7, 4.0), NS
| | n = 1 | | | ≥ [underlined: 1,200 mg/d] (1 RCT): OR: 2.8 (1.3, 5.7), S
| | Range years | | | Hospitalization for GI Bleed: (3 RCTs)
| | NR-1990 | | | OR: 1.9 (99% CI: 1.1, 3.1), S
| | Quality of SR | | | GI symptoms*: (7 RCTs)
| | Fair | | | OR: 1.7 (99% CI: 1.5, 1.8), S

N = number of participants; y = year(s); mo = month(s); wk = week(s); d = day(s); n = number; pts = patients; hx = history; NR = not reported; vs. = versus; pb = placebo; ASA = acetylsalicylic acid/aspirin; RCT(s) = randomized control trial(s); NSAID = non steroid anti-inflammatory drug; RR = relative risk; MI = myocardial infarction; OAD = oral coagulation drug; INR = international odds ratio; CABG = coronary artery bypass graft; PTCA =percutaneous coronary angioplasty; NS = nonstatistically significant difference; S = statistically significant difference; CVD = cardiovascular disease; SR = systematic review; OR = odds ratio; GI = gastrointestinal; AAR = absolute risk reduction; NNT = number needed to treat; BP = blood pressure; HTN = hypertension; CV = cardiovascular; CHF = congestive heart failure; UGIC = upper gastrointestinal complications

Evidence Table 3.2. Harms due to non-aspirin NSAID (other than COX-2 inhibitors)—Systematic reviews

Author, year | N | Review characteristics/ quality | Eligibility criteria | Intervention(s) (dose range) | Results
Tramer, 2000 ^54^ | RCT: 19,364 | Included studies | Inclusion; - Gastric or duodenal ulcer, ulcer hemorrhage or perforation, death due to these events; - Oral NSAID or ASA exposure > 2 mo; - Any level of evidence | NSAID vs. pb or non users | Average GI bleeding rate: 4.8%
| Cohorts: | RCTs = 15 | Exclusion; - Abstracts & reports of NSAID-induced complications other than Upper GI | | GI ulcer bleed or perforation:
| 215,076 | Cohorts = 3 | | | (3 RCTs) Absolute Risk Difference: 0.48%
| Case-control: | Case-controls = 6 | | | (1 Cohort): Absolute Risk Difference: 0.22%
| 2,957 cases | e-databases | | | Mortality due to GI events: (RCT & cohort) 0.008% NNT: 16,932
| | n = 2
| | Range years
| | NR - 1996
| | Quality of SR
| | Fair
Huang, 2002 ^56^ | 734 | Included studies | Inclusion; - Harms of ASA/NSAID; - Roles of helicobacter pylori infection & NSAID drugs in the occurrence of peptic ulcer disease, GI harms; - Incidence/prevalence of PUD in NSAIDs adult users or prevalence of H pylori infection & NSAID use amongst pts with PUB; influence of H pylori & NSAID use on the rate of PUD; - Cross-sectional, case-control, or cohort | NSAIDs users vs. no users | PUB:
| | Cohort = 1 | Exclusion; - Abstracts; - Antibiotic &/or anti-ulcer drug use 3–4 wks before study entry; - Hx gastric surgery; - Non-ulcer GI bleeding, gastric tumors; - Pts taking corticosteroids or anticoagulants | | OR: 4.79 (3.78, 6.06), S
| | Case-control = 7 | | | Endoscopic GI ulcers >5mm:
| | e-databases | | | OR: 5.14 (1.35, 19.6), S
| | n = 3
| | Range years
| | 1984 - 2000
| | Quality of SR
| | Fair
Ofman, 2002 ^57^ | RCTs: 4,431 | Included studies | Inclusion; - Subjects ≥ 18 y; - Oral NSAIDs ≥ 5 d; - Serious upper GI complications: PUB (perforation, ulcer, & bleeding); - RCTs, cohort & case-control studies | NSAIDs vs. pb (RCTs) | PUB:
| Cohorts: 758,776 pt-y | RCTs: n = 92 | Exclusion; - Studies not reporting PUB, animal studies, studies reporting the use of non-oral NSAIDs or ASA alone, studies not reporting inclusion criteria, reviews, editorials, letters, clinical practice guidelines, case-reports, case-series, or consensus statements, studies reporting the duration of NSAIDs use < 5 d | NSAIDs users vs. non users (cohorts) | [underlined: (16 RCTs):] OR: 5.36 (1.79, 16.1), S
| Case-controls:25,732 | Cohorts: n = 24 | | | [underlined: (9 Cohorts):] RR: 2.7 (2.1, 3.5), S
| | Case-controls: n = 57 | | | [underlined: (23 case-controls):] OR: 3.0 (2.5, 3.7), S
| | e-databases
| | n = 4
| | Range years
| | 1966 - 1998
| | Quality of SR
| | Good
Ofman, 2003 ^58^ | 12,000 | Included studies | Inclusion; - Subjects > 18 y; - NSAID use > 5 d; - Dyspepsia; - RCT, case-control, cohort, exposure | NSAIDs v. pb | [underlined: NSAID vs. control]
| | RCTs: n = 48 | Exclusion; - Animal studies, studies reporting the use of non-oral NSAIDs or ASA alone, reviews, editorials, letters, clinical practice guidelines, case-reports, case-series, or consensus statements; - NSAID < 5 d | | Dyspepsia rate: 4.8% (3.8, 5.8), S
| | e-databases | | | High dose - Dyspepsia:
| | n = 4 | | | Risk ratio: 2.6 (1.5, 4.5), S
| | Range years | | | Low Dose - Dyspepsia:
| | 1966 - 1998 | | | Risk ratio: 1.3 (0.9, 1.8), NS
| | Quality of SR | | | [underlined: Indomethacin, meclofenamate & piroxicam]
| | Good | | | Dyspepsia:
| | | | | Risk ratio: 2.2 (1.5, 3.2), S
Rostom, 2003 ^59^ | 4,675 | Included studies | Inclusion; - OA pts, RA > 18 y, chronic use (> 4 wks) NSAID | Celecoxib vs. NSAID (naproxen, diclofenac, ibuprofen) | % pts with endoscopic ulcers
| | RCTs: n = 37 | Exclusion; - NR | Rofecoxib vs. NSAID | (NSAIDs): 19% gastric; 6% duodenal
| | e-databases | | All Cox-2 vs. NSAID | Clinically important ulcers:
| | n = 8 | | | 1.5% / y - average OA, RA pt; up to 9%/y high risk of GI complications
| | Range years
| | 1966 - 2002
| | Quality of SR
| | Good

N = number of participants; y = year(s); mo = month(s); wk = week(s); d = day(s); n = number; pts = patients; hx = history; NR = not reported; vs. = versus; pb = placebo; ASA = acetylsalicylic acid/aspirin; RCT(s) = randomized control trial(s); NSAID; = non steroid anti-inflammatory drug; ARR = absolute risk reduction; OR = odds ratio; MI = myocardial infarction; NS = nonstatistically significant difference; S = statistically significant difference; GI = gastrointestinal; SR = systematic review; NNT = number needed to treat; PUD = peptic ulcer disease; H pylori = Helicobacter pylori; PUB = perforation ulcer bleed; RR = relative risk; GI = gastrointestinal; SR = systematic review; Cox-2 = Cox-2 inhibitors; OA = osteoarthritis; RA = rheumatoid arthritis

Evidence Table 3.3. Harms due to COX-2 inhibitors—Systematic reviews

Author, year | N | Review characteristics/ quality | Eligibility criteria | Intervention(s) (dose range) | Results
Hooper, 2004 ^60^ | 74,666 | Included studies | Inclusion; - COX-2 vs. NSAID, misoprostol, PPI and H2; - GI, CV, renal, other harms; - RCTs | COX 2- selective (etodolac, meloxicam, nabumetone, nimesulide) vs. NSAIDs | All-cause mortality:
| | RCTs: n = 68 | Exclusion; - Non-RCTs; - No treatment; - Children; - < 21 d study period | COX-2 specific (celecoxib, rofecoxib) vs. NSAIDs | [underlined: Cox-2 selective (51 RCTs):]
| | e-databases | | | RR: 0.68 (0.3, 1.6), NS
| | n = 3 | | | [underlined: Cox-2 specific (17 RCTs):]
| | Range years | | | RR: 1.02 (0.6, 1.9), NS
| | 1966 - 2002 | | | Withdrawals due to harms:
| | Quality of SR | | | [underlined: Cox-2 selective (51 RCTs):]
| | Good | | | RR: 0.93 (0.9, 1.0), NS
| | | | | [underlined: Cox-2 specific (17 RCTs):]
| | | | | RR: 0.82 (0.7, 0.9)^
| | | | | Endoscopic GI ulcers:
| | | | | [underlined: Cox-2 selective (51 RCTs):]
| | | | | RR: 0.41 (0.2, 1.1), NS
| | | | | [underlined: Cox-2 specific (17 RCTs):]
| | | | | RR: 0.25 (0.2, 0.3), S
| | | | | Symptomatic ulcers:
| | | | | [underlined: Cox-2 selective (51 RCTs):]
| | | | | RR: 0.41 (0.3, 0.7), S
| | | | | [underlined: Cox-2 specific (17 RCTs):]
| | | | | RR: 0.49 (0.38, 0.62), S
| | | | | POB:
| | | | | [underlined: Cox-2 selective (51 RCTs):]
| | | | | RR: 0.61 (0.34, 1.10), NS
| | | | | [underlined: Cox-2 specific (17 RCTs):]
| | | | | RR: 0.55 (0.38, 0.80), S
| | | | | GI symptoms:
| | | | | [underlined: Cox-2 selective (51 RCTs):]
| | | | | RR: 0.73 (0.7, 0.8), S
| | | | | [underlined: Cox-2 specific (17 RCTs):]
| | | | | RR: 0.81 (0.7, 0.9), S
Garner, 2002 ^61^ | 4,465 | Included studies | Inclusion; - RA pts (some with OA); - RCTs; - Published; - celecoxib vs. pb; - celecoxib vs. other NSAID | Celecoxib vs. pb | [underlined: Celecoxib vs. pb] :All-cause mortality: (3 RCTs) None; - Withdrawals due to harms: (1 RCT); Cel 40mg (4%) vs. 200 mg (5%) vs. 400 mg (5%) vs. pb (6%), NS; - Edema: (2 RCTs); Cel 1–2% vs. pb 0%; - Endoscopic ulcers: NS
| | RCTs: n = 5 | Exclusion; - <50 pts in each arm; - <1mo treatment | Celecoxib vs. NSAIDs | [underlined: Celecoxib vs. NSAIDs:]; - Arterial hypertension: (1 RCT) Cel 4/236 (1%) vs. diclofenac 5/329 (2%); - Edema: (3 RCTs); Cel (400–800 mg/d) & naproxen 2%; Cel 11/236 (3%) vs. diclofenac 5/329 (2%); - Endoscopic ulcers: (2 RCTs); RR: 0.22 (0.15–0.32), S; Used FDA CLASS study description; - Endoscopic ulcers: (52 wks); Celecoxib (22/3105) was S lower than for the NSAID's pooled (39/ 3,124; p=0.02) & for ibuprofen alone (29/ 1,573; p=0.001) but not for diclofenac alone (29/1,573)
| | e-databases | | Used FDA CLASS study description
| | n = 3
| | Range years
| | 1966 - 2002
| | Quality of SR
| | Good
Deeks, 2002 ^62^ | 15,187 | Included studies | Inclusion; - OA/ RA | Celecoxib vs. pb | [underlined: Celecoxib vs. pb]; - Withdrawals due to harms: (5 RCTs); RR: 1.49 (1.15, 1.92), S; - Endoscopic GI ulcers: RR: 1.53 (0.73, 3.21), NS
| | RCTs: n = 9 | Exclusion; - NR | Celecoxib vs. NSAIDs | - [underlined: Celecoxib vs. NSAIDs]; - Withdrawals due to harms: (8 RCTs); RR: 0.86 (0.72, 1.04), NS; - Endoscopic GI ulcers: (vs. naproxen, diclofenac): RR: 0.25 (0.12, 0.53); - POB: (vs. ibuprofen, diclofenac); RR: 0.55 (0.26, 1.14), NS; - PUB: (vs. ibuprofen, diclofenac); RR: 0.61 (0.39, 0.96), S
| | e-databases
| | n = 3
| | Range years
| | 1998 - 2001
| | Quality of SR
| | Fair
Edwards, 2004 ^63^ | 5,726 | Included studies | Inclusion; - Pts: OA or RA; - Double-blind RCTs; - Valdecoxib vs. pb or NSAIDs | Valdecoxib 10 –20 mg/d vs. pb | [underlined: Valdecoxib vs. pb:]; - Withdrawals due to harms: RR: 0.9 (0.7, 1.3), NS; - Significant renal events: RR: 2.9 (1.4, 5.7), S; - Endoscopic GI ulcers: RR: 0.9 (0.5, 1.6), NS
| | RCTs: n = 9 | Exclusion; - NR | Valdecoxib 10 –20 mg/d vs. NSAIDs (ibuprofen, diclofenac, naproxen) | [underlined: Valdecoxib vs. NSAIDs:] (9 RCTs); - Withdrawals due to harms: RR: 0.6 (0.5, 0.7), S; - Acute MI: Valdecoxib 3/2,733 (0.1%) vs. NSAID 11/1,846 (0.6%), S; - Edema: 2% each group, NS; - Significant renal events: RR: 0.7 (0.5, 1.0), NS; - Endoscopic GI ulcers: RR: 0.4 (0.3, 0.5), S; - POB: RR: 0.4 (0.2, 1.2), NS
| | e-databases
| | NR
| | Range years
| | 2002 - 2003
| | Quality of SR
| | Good
Garner, 2005 ^64^ | NR | Included studies | Inclusion; - Pts with OA any age or sex; - Published RCTs; - Rofecoxib vs. pb or active comparators; - Efficacy & safety outcomes | Rofecoxib vs. pb | [underlined: Rofecoxib vs. pb:]; - Withdrawals due to harms: (6 RCTs); [underlined: 12.5 mg/d:] RR: 2.18 (1.34–3.55), S; [underlined: 25 mg/d:] RR: 1.56 (0.94, 2.59); [underlined: 50 mg/d]: RR: 2.04 (1.24, 3.36), S; - All symptoms and endoscopic ulcers: NS; - Total adverse events: RR: 1.32 (1.11, 1.56) @ 6 wks; longer durations, NS
| | RCTs: n = 26 | Exclusion; - Unpublished RCTs | Rofecoxib vs. NSAIDs (diclofenac, naproxen, ibuprofen, nimesulide, nabumetone, paracetamol, celecoxib) | [underlined: Rofecoxib vs. diclofenac (150 mg/d):]; - Withdrawals due to harms: (2 RCTs); [underlined: 12.5 mg/d:] RR: 0.71 (0.52–0.97); [underlined: 25 mg/d]: RR: 0.70 (0.51–0.95); - PUB: RR: 0.25 (0.03, 2.25), NS
| | e-databases | | | [underlined: Rofecoxib vs. naproxen:] (1 RCT); - Acute MI: RR: 4.98 (0.58, 42.57), NS; - Acute stroke: RR: 0.08 (0.00, 1.36), NS; - Arterial hypertension: RR: 1.22 (0.89, 1.68), NS; - PUB: RR: 0.14 (0.01, 2.77), NS
| | n = 3 | | | [underlined: Rofecoxib vs. nabumetone:] (3 RCTs); - Arterial hypertension: RR: 1.46 (0.53, 4.12), NS; - Edema: RR: 1.41 (0.72, 2.77), NS
| | Range years | | | [underlined: Rofecoxib vs. ibuprofen:]; - Endoscopic GI ulcers: RR: 0.28 (0.19, 0.42), S; - PUB: RR: 0.25 (0.03, 2.26), NS
| | 1966 - 2004 | | | [underlined: Rofecoxib (25 mg) vs. celecoxib (200 mg):]; - Withdrawals due to harms: (9 RCTs); RR: 1.03 (0.77, 1.39), NS; - Arterial hypertension: (2 RCTs); RR: 3.51 (0.73, 16.84), NS; - Edema: RR: 1.39 (0.63, 3.08), NS
| | Quality of SR
| | Good
Garner, 2005 ^65^ | NR | Included studies | Inclusion; - Pts with RA any age or sex; - RCTs; - Rofecoxib vs. pb or active comparators; - Efficacy & safety outcomes | Rofecoxib (12.5–50 mg/d) vs. pb | [underlined: Rofecoxib vs. pb:]; - Withdrawals due to harms:; Rofe 5 mg (3%) vs. 25 mg (3.2%) vs. 50 mg (4.7%) vs. pb (6.2%), NS; - GI outcomes: NS; - Edema & hypertension: NS between 3 doses of rofecoxib & pb.
| | RCTs: n = 2 | Exclusion; - < 50 pts included in RCT; - Duration treatment < 4 wks; - Used concomitant intra-articular corticosteroid therapy | Rofecoxib (12.5–50 mg/d) vs. naproxen (1 g/d) | [underlined: Rofecoxib vs. naproxen (VIGOR):]; - All-cause mortality: 0.5% vs. 0.4%, NS; - CV-mortality: both 0.2%, NS; - Withdrawals due to harms: (1 RCT); RR: 1.02 (0.92, 1.12), NS; - Acute MI: (1 RCT); RR: 5.0 (1.5, 13.2), S; - All-acute stroke: (1 RCT); RR: 1.37 (0.55, 3.41), NS; - Ischemic stroke: RR: 1.12 (0.43, 2.91), NS; - TIA: RR: 4.98 (0.24, 103.77), NS; - POB: RR: 0.43 (0.24, 0.77), S
| | e-databases
| | n = 5
| | Range years
| | 1966 - 2000
| | Quality of SR
| | Good
Gomez Cerezo, 2003 ^66^ | 45,761 | Included Studies | Inclusion; - Cox 2 specific; - RCTs | Rofecoxib (12.5–50 mg/d) or celecoxib (50–800 mg/d) vs. NSAIDs (naproxen 1g/d, ibuprofen 2.4 g/d, diclofenac 100–150 mg/d) or pb | [underlined: Rofecoxib vs. naproxen]; - HTN (withdrawals): (1 RCT) RR: 4.67 (1.93, 11.28), S; - CHF: (1 RCT): RR: 2.11 (0.96, 4.67), NS; - Edema (withdrawals): (1 RCT); RR: 1.92 (0.98, 3.75), NS; - PUB: RR: 0.46 (0.34, 0.63), S; - POB: RR: 0.43 (0.24, 0.77), S; rofecoxib vs. Ibuprofen & diclofenac:; - PUB: RR: 0.51 (0.26, 1), NS
| | RCTs: n = 3 | Exclusion; - non-English | | [underlined: Celecoxib vs. NSAID]; - POB: RR: 0.10 (0.01, 0.81), S; celecoxib vs. Ibuprofen & diclofenac:; - POB: RR: 0.60 (0.25, 1.40), NS; - PUB: RR: 0.61 (0.39, 0.96), S
| | e-databases
| | n = 1
| | Range years
| | 1998 - 2002
| | Quality of SR
| | Poor
Mukherjee, 2001 ^67^ | 18,064 | Included studies | Inclusion; - Pts without previous CV event; - COX-2 (rofecoxib, celecoxib); - Double-blind RCT | Rofecoxib (50 mg/d) vs. naproxen (1 g/d) | [underlined: Rofecoxib vs. naproxen:] (1 RCT); - Serious CV events:; Low CV risk: RR: 1.89 (1.03, 3.45), S; High risk (ASA indicated): RR: 4.89 (1.41, 16.88), S
| | RCTs: n = 4 | Exclusion; - Non-RCTs, RCTs reporting non-CV adverse events
| | e-databases
| | n = 1
| | Range years
| | 1998 - 2001
| | Quality of SR
| | Fair
Juni, 2004 ^68^ | 25,273 | Included studies | Inclusion; - RCTs & observational studies; - Rofecoxib vs. NSAID or pb; - Pts with chronic musculoskeletal disorders; - Fatal or nonfatal MI, stroke, CV mortality, serious CV events | Rofecoxib vs. pb or NSAIDs | [underlined: Rofecoxib vs. NSAIDS] : (9–17 RCTs); - Acute MI: RR: 2.24 (1.24, 4.02), S; - Stroke/TIA: RR: 1.02 (0.54, 1.93), NS; - Death due to CV harms:; RR: 0.79 (0.29, 2.19), NS; - Serious CV events: RR: 1.55 (1.05, 2.29), S
| | RCTs: n = 18 | Exclusion; - NR | | [underlined: Rofecoxib vs. pb:]; - Acute MI: RR: 1.04 (0.34, 3.12), NS
| | Case-control: n = 8 | | | [underlined: Rofecoxib vs. no naproxen NSAID:]; - Acute MI: RR: 1.55 (0.55, 4.36), NS
| | e-databases | | | [underlined: Rofecoxib vs. naproxen:]; - Acute MI: RR: 2.93 (1.36, 6.33), S; [underlined: 12.5 mg/d] RR: 2.71 (0.99, 7.44), NS; [underlined: 25 mg/d] RR: 1.37 (0.52, 3.61), NS; [underlined: 50 mg/d] RR: 2.83 (1.24, 6.43), S
| | n = 4
| | Range years
| | 1966 - 2004
| | Quality of SR
| | Good
Rostom, 2003 ^59^ | 86,702 | Included studies | Inclusion; - OA pts, RA > 18 y, chronic use (> 4 wks) NSAID | Celecoxib vs. NSAID (naproxen, diclofenac, ibuprofen) | [underlined: Celecoxib vs. NSAID:]; - Endoscopic ulcers: RR: 0.28 (0.23, 0.35), S
| | RCTs: n = 37 | Exclusion; - NR | Rofecoxib vs. NSAID | [underlined: Celecoxib vs. diclofenac:]; - Endoscopic ulcers: RR: 0.45 (0.15, 1.29), NS
| | e-databases | | All Cox-2 vs. NSAID | [underlined: Rofecoxib vs. NSAIDs:]; - Endoscopic ulcers: RR: 0.25 (0.20, 0.32), S
| | n = 8 | | | [underlined: Meloxicam vs. NSAIDs:]; - POB: RR: 0.50 (0.22 –1.17), NS
| | Range years | | | [underlined: All Cox 2 vs. NSAIDs:]; - POB: RR: 0.45 (0.32, 0.63), S; - Endoscopic ulcers: RR: 0.27 (0.23, 0.32), S
| | 1966 - 2002
| | Quality of SR
| | Good
Ashcroft, 2001 ^69^ | 4,632 | Included studies | Inclusion; - Pts with RA & OA who had scheduled endoscopies; - Celecoxib; - RCTs | Celecoxib vs. NSAIDs (ibuprofen, diclofenac, naproxen) or pb | - Endoscopic ulcers:
| | RCTs: n = 5 | Exclusion; - Healthy population not undergone by endoscopy | | [underlined: Celecoxib vs. naproxen:]
| | e-databases | | | 200 mg/d: RR: 0.22 (0.13, 0.37), S
| | n = 3 | | | 400 mg/d: RR: 0.24 (0.17, 0.33), S
| | Range years | | | [underlined: Celecoxib vs. diclofenac:]
| | 1988 - 2000 | | | 12 wks: RR: 0.73 (0.45, 1.2), NS
| | Quality of SR | | | 24 wks: RR: 0.24 (0.11, 0.52), S
| | Fair | | | [underlined: Celecoxib vs. Ibuprofen:]
| | | | | RR: 0.30 (0.20, 0.46), S
| | | | | [underlined: Celecoxib vs pb:]
| | | | | 200 mg/d: RR:1.96 (0.85, 4.55)
| | | | | 400 mg/d: RR:2.35 (1.02, 5.38)
Goldstein, 2004 ^70^ | 10,305 | Included studies | Inclusion; - Pts with RA and/or OA; - RCTs (long-term, open-label) | Valdecoxib vs. pb or NSAIDs | [underlined: Valdecoxib vs. pb:]; - PUB: RR :3.8 (0.22–65.70), NS
| | RCT: n=8 | Exclusion; - NR | | Valdecoxib vs. NSAIDs:; - POB (8 RCTs): (Valdecoxib 0.69%; NSAIDs 1.96%) RR: 0.14 (0.04–0.51), S; [underlined: Non - ASA users]: (Valdecoxib 0.29%; NSAIDs 2.08%): RR: 0.35 (0.14–0.87), S
| | Cohorts: n = 3 | | | Valdecoxib + ASA = 9-fold increase risk of bleeding
| | e-databases | | | NSAIDS + ASA = did not increase risk further
| | NR | | | Open-label: dose-reponse not seen with valdecoxib
| | Range years
| | NR
| | Quality of SR
| | Fair
Schoenfeld, 1999 ^71^ | 20,374 | Included studies | Inclusion; - Adult pts; - Meloxicam vs. other non-COX 2 NSAID; - GI events: dyspepsia, nausea/vomiting, abdominal pain, diarrhea, perforations, ulcers, bleeds, & withdrawals due to GI events; - RCTs (including crossover with washout period) | Meloxicam (7.5 to 15 mg) vs. NSAID | - Overall GI harms: OR: 0.64 (0.59, 0.69), S; - PUB: OR: 0.52 (0.28, 0.96), S; - Dyspepsia: OR: 0.73 (0.64, 0.84), S; - Withdrawals due to GI harms:; OR: 0.59 (0.52, 0.67), S
| | RCTs: n = 10 | Exclusion; - NR
| | e-databases
| | n = 1
| | Range years
| | 1990 - 1998
| | Quality of SR
| | Fair
Eisen, 2005 ^72^ | 4,394 | Included studies | Inclusion; - Adult pts ≥ 18 y withOA or RA; - Phase III RCTs; - Valdecoxib use | Valdecoxib (10–20 mg/d) vs. pb or other NSAIDs (ibuprofen, diclofenac, naproxen) | - Dyspepsia:; Valdecoxib vs. NSAIDs: HR =1.0; Valdecoxib vs. pb:; Valdecoxib: HR = 0.56 (0.45–0.69); Pb: HR= 0.59 (0.45–0.79)
| | RCTs: n = 5 | Exclusion; - Pts with concomitant GI, renal, hepatic or coagulation disorder or malignancy
| | e-databases
| | NR
| | Range years
| | NR
| | Quality of SR
| | Fair

N = number of participants; y = year(s); mo = month(s); wk = week(s); d = day(s); n = number; pts = patients; hx = history; NR = not reported; vs. = versus; pb = placebo; ASA = acetylsalicylic acid/aspirin; RCT(s) = randomized control trial(s); NSAID = non steroid anti-inflammatory drug; RR = relative risk; OR = odds ratio; NS = nonstatistically significant difference; S = statistically significant difference; ⁁ high heterogeneity; GI = gastrointestinal; SR = systematic review; Cox-2 = Cox-2 inhibitors; PPI = proton pump inhibitors; H2 = H2 blockers; CV = cardiovascular; OA = osteoarthritis; RA = rheumatoid arthritis; FDA = food and drug administration; Cel = celecoxib; POB = perforation obstruction, bleed; PUB = perforation ulcer bleed; CHF = congestive heart failure; TIA = transitory ischemic attack; HTN = arterial hypertension

Evidence Table 4.1. Cost-effectiveness analysis—Suleiman 2002 ^73^

Study type | Decision analysis using a Markov model
Interventions | 1 Do nothing; 2 Colonoscopy q10 y; q3 y if polyp(s) found; 3 ASA 325mg po daily; 4 Colonoscopy q10 y + ASA 325mg po daily
Study population | 100 000 average-risk subjects age 50 followed until death
Economical context | Third-party payer perspective in U.S. dollars discounted at 3% per year
Probabilities (range used in sensitivity analysis) | Incidence polyps: 0.01/yr
| Age-specific incidence CRC: from SEER data 1973-94
| Efficacy of colonoscopy at preventing CRC: 75% (50–75%)
| Efficacy of ASA at preventing CRC: 50% (25–75%)
| Efficacy of ASA+colonoscopy at preventing CRC: 87.5% (50–100%)
| Mortality from CRC: 40%
| Effect of ASA on cardiovascular outcomes: not modeled
| Compliance to interventions: 100%
Costs (range used in sensitivity analysis) | ASA: $172/PY ($20–200) (includes costs of complications)
| Colonoscopy: $696
| Colonoscopy with polypectomy: $1004
| Care for CRC: $45 228 (up to $60 000)
Outcomes | Screening vs do nothing:; - saves 7,951 LYs for $223,780,829; - ICER $10,983/LY saved
| ASA vs do nothing:; - Saves 5,301 LYs for $386,920,810; - ICER $47,249/LY saved
| ASA + screening vs do nothing; - ICER $41,929/LY saved
| ASA+screening vs screening alone; - ICER $227,607/LY saved
Sensitivity Analyses | Cost of ASA (including drug cost and cost of complications) needs to fall below $70/patient/y for ASA to be more cost-effective than screening

Evidence Table 4.2. Cost-effectiveness analysis—Ladabaum 2001 ^74^

Study type | Decision analysis using a Markov model
Interventions | 1 Do nothing; 2 Flexible sigmoidoscopy q5 y + FOBT q1y (FS/FOBT); 3 Colonoscopy q10 y; q5 y if polyp(s) found (COLON); 4 ASA 325mg po daily; 5 FS/FOBT + ASA 325mg po daily; 6 Colonoscopy q10 y + ASA 325mg po daily
Study population | Average-risk subjects age 50 followed for 30 years
Economical context | Third-party payer perspective in U.S. dollars discounted at 3% per year
Probabilities (range used in sensitivity analysis) | Incidence polyps: 0.011/yr at age 50–60 to 0.019/y age 70+
| Baseline prevalence polyps: 15%
| Age-specific incidence CRC: from SEER data 1973-94
| FOBT: sensitivity CRC 40% (30–60%); polyps 10% (5–15%)
| FS: sensitivity Lt-sided CRC 90% (80–95%)
| % Lt-sided CRC: 50%
| COLON: sensitivity CRC 95% (90–97%); polyps 90% (85–95%)
| Efficacy of ASA at preventing CRC: 30% (5–55%)
| Incidence ASA-related morbidity:
| <65y: 2 (0.5–5)/10 000PYs; >/= 65y: 16 (4–40)/10 000PYs
| Incidence ASA-related mortality: 5% (2–8%)
| Compliance w interventions: 25%
Costs (range used in sensitivity analysis) | ASA: $4/PY ($20–200)
| Major ASA-related complication: $15 000 ($10 000–$20 000)
| FOBT: $10 ($5–15)
| FS: $206 ($76–336)
| Colonoscopy: $623 ($288–958)
| Care for advanced CRC: $40 000 ($30 000–50 000)
Outcomes | Screening vs do nothing; - ICER FS/FOBT $16,844/LY saved; - ICER COLO $20,172/LY saved
| ASA + screening vs screening alone; - increased costs and decreased LYs
| If ASA decreased cardiovascular mortality by 0.1% and CRC incidence by 30%:; - ICER ASA + FS/FOBT vs FS/FOBT alone $10,039/LY saved; - ICER ASA + COLO vs COLO alone $8,976/LY saved
Sensitivity Analyses | ASA use affects both polyp and CRC growth vs only CRC growth
| Effect of ASA on cardiovascular outcomes: nil vs reduction
| Effect of ASA on FOBT: nil vs increased sensitivity and decreased specificity

Evidence Table 4.3. Cost-effectiveness analysis—Ladabaum 2003 ^75^

Study type | Decision analysis using a Markov model
Interventions | 1 Do nothing; 2 Colonoscopy q10 y in avrg risk; q5 y in at-risk subjects; 3 Daily COX-2 inhibitors; 4 Colonoscopy q10 y in avrg risk/q5 y in at-risk + daily COX-2 inhibitors
Study populations | 1 Average-risk subjects age 50 followed for 30 years; 2 At-risk subjects age 50 followed for 30 years; a With 1 1st degree rel w CRC (RR 2.6avrg); b With 2 1st degree rel w CRC (RR 3.6avrg)
Economical context | Third-party payer perspective in U.S. dollars discounted at 3% per year
Probabilities (range used in sensitivity analysis) | Incidence polyps in avrg risk: 0.011/yr at age 50–60 to 0.019/y age 70+
| Baseline prevalence polyps: 15%
| Age-specific incidence CRC: from SEER data 1973-94
| Colonoscopy: sensitivity CRC 95% (90–97%); polyps 90% (85–95%)
| Efficacy of COX-2 at preventing CRC: 30% (0–100%)
| Incidence COX-2-related morbidity:
| Nil (0–0.1%/y)
| Incidence COX-2-related mortality: nil (2–8%)
Costs (range used in sensitivity analysis) | COX-2: $365/PY ($91.25–$1 460/PY)
| Major COX-2-related complication: $15 000 ($10 000–$20 000)
| Colonoscopy: $623 ($288–958)
| Care for advanced CRC: $40 000 ($30 000–50 000)
Sensitivity Analyses | Varying COX-2's chemopreventive efficacy from 0 to 100%
| Assuming a differential effect on polyp and CRC growth
| Using a COX-2 inhibitor in individuals younger than 65
| Increasing the rate of excess major GI complications to 0.1%/year
| Varying rate of death from COX-2 from 2 to 8% per complication
| Varying the doses of COX-2's, with yearly costs of COX-2 chemoprevention ranging from $81.25 to $1300
| Evaluating whether COX-2 chemoprevention would allow for less frequent screening
Outcome | Colonoscopy vs do nothing; - saves 0.065LY/person; ICER $20,200/LY saved
| COX-2 vs do nothing; - saves 0.027LY/person; ICER of $233,300/LY saved
| COX-2 + colon vs colon alone; - saves 0.008LY/person; ICER $823,800/LY saved
| COX-2 use alone would need to reduce CRC risk by 60% at a cost of $0.25/day to approach the cost effectiveness of colonoscopy every 10 years

Evidence Table 4.4. Cost-effectiveness analysis—Arguedas 2001 ^76^

Study type | Decision analysis using a Markov model
Interventions | 1 Do nothing; 2 Colonoscopy every 3 years; every 5 years if no polyp found; 3 Celecoxib 200mg po daily
Study population | 50 yo subjects with colonic adenomas followed for 10 years
Economical context | Third-party payer perspective in U.S. dollars discounted at 3% per year
Probabilities (range used in sensitivity analysis) | Incidence polyps: 0–3 yrs: 0.106/y (0.05–0.20); after 3 yrs: 0.05/y (0.02–0.15)
| Incidence CRC: 0.10/y (0.05–0.20)
| Efficacy of celecoxib at preventing CRC: 50% (0–100%)
| Incidence of celecoxib-induced PUD: 0.02/y (0.01–0015)
| Incidence withdrawal re celecoxib SE: 0.01/y (0–0.02)
| Compliance w intervention: 100%
| Effect of celecoxib on cardiovascular outcomes: not modeled
Costs (range used in sensitivity analysis) | ASA: $172/pt/yr ($20–200)
| Colonoscopy: $514 ($300–750)
| Colonoscopy with polypectomy: $658 ($500–1000)
| Care for CRC: $100 000/case ($10,000–250,000)
Outcomes | Colonoscopy vs do nothing; - 0.01995LY saved at a cost of $558; - ICER $27, 970/LY saved
| Celecoxib vs do nothing; - 0.00579LY saved for $9,931; - ICER $407,498/LY saved
| Celecoxib use could be economically advantageous (ICER less than $50,000/LY saved) if 50% effective for polyp prevention at a cost of $0.10/day or if 75% effective at a cost of $0.35/day
| Results not sensitive to the rate of polyp formation (i.e. increasing or decreasing the magnitude of patient risk)

Evidence Table 4.5. Cost-effectiveness analysis—Hur 2003 ^77^

Study type | Decision analysis using a Markov model
Interventions | 1 ASA 325mg po daily; 2 Celecoxib 200mg po bid
Study population | Average-risk men age 50 followed for 10 years
Economical context | Societal perspective in U.S. dollars discounted at 3% per year
Probabilities (range used in sensitivity analysis) | Incidence polyps: 0.01/yr
| Age-specific incidence CRC: from SEER data 1973-94
| Efficacy of ASA at preventing CRC: 50% (25–75%)
| Efficacy of ASA+colonoscopy at preventing CRC: 87.5% (50–100%)
| Mortality from CRC: 40%
| Effect of ASA on cardiovascular outcomes: not modeled
Costs (range used in sensitivity analysis) | ASA: $172/pt/yr ($20–200)
| Colonoscopy: $696
| Colonoscopy with polypectomy: $1004
| Care for CRC: $45 228 (up to $60 000)
Outcomes | ASA; - 7.60 QALY saved for $181
| Celecoxib; - 7.57 QALY saved for $23,403
Sensitivity Analyses | Coxibs become more effective than ASA if; - the relative ulcer rate on coxibs is 93% lesser than in the base-case; - the combined relative MI/ulcer rate for coxibs is decreased by 60%; - the relative bleeding rate on ASA is increased 550%

## References for Appendix 8

1 Bigler J, Whitton J, Lampe JW, et al. CYP2C9 and UGT1A6 genotypes modulate the protective effect of aspirin on colon adenoma risk. Cancer Res. 2001;61(9):3566-3569. [pmid: 11325819].
2 Martinez ME, McPherson RS, Levin B, et al. Aspirin and other nonsteroidal anti-inflammatory drugs and risk of colorectal adenomatous polyps among endoscoped individuals. Cancer Epidemiol Biomarkers Prev. 1995;4(7):703-707. [pmid: 8672985].
3 Logan RF, Little J, Hawtin PG, et al. Effect of aspirin and non-steroidal anti-inflammatory drugs on colorectal adenomas: case-control study of subjects participating in the Nottingham faecal occult blood screening programme. BMJ. 1993;307(6899):285-289. [pmid: 8374373].
4 Suh O, Mettlin C, Petrelli NJ. Aspirin use, cancer, and polyps of the large bowel. Cancer. 1993;72(4):1171-1177. [pmid: 8339210].
5 Hauret KG, Bostick RM, Matthews CE, et al. Physical activity and reduced risk of incident sporadic colorectal adenomas: observational support for mechanisms involving energy balance and inflammation modulation. Am J Epidemiol. 2004;159(10):983-992. [pmid: 15128611].
6 Lieberman DA, Prindiville S, Weiss DG, et al. Risk factors for advanced colonic neoplasia and hyperplastic polyps in asymptomatic individuals. JAMA. 2003;290(22):2959-2967. [pmid: 14665657].
7 Martin C, Connelly A, Keku TO, et al. Nonsteroidal anti-inflammatory drugs, apoptosis, and colorectal adenomas. Gastroenterology. 2002;123(6):1770-1777. [pmid: 12454832].
8 Garcia Rodriguez LA, Huerta-Alvarez C. Reduced incidence of colorectal adenoma among long-term users of nonsteroidal antiinflammatory drugs: a pooled analysis of published studies and a new population-based study. Epidemiology. 2000;11(4):376-381. [pmid: 10874542].
9 Breuer-Katschinski B, Nemes K, Rump B, et al. Long-term use of nonsteroidal antiinflammatory drugs and the risk of colorectal adenomas. The Colorectal Adenoma Study Group. Digestion. 2000;61(2):129-134. [pmid: 10705177].
10 Kahn HS, Tatham LM, Thun MJ, et al. Risk factors for self-reported colon polyps. J Gen Intern Med. 1998;13(5):303-310. [pmid: 9613885].
11 Sandler RS, Galanko JC, Murray SC, et al. Aspirin and nonsteroidal anti-inflammatory agents and risk for colorectal adenomas. Gastroenterology. 1998;114(3):441-447. [pmid: 9496933].
12 Peleg II, Lubin MF, Cotsonis GA, et al. Long-term use of nonsteroidal antiinflammatory drugs and other chemopreventors and risk of subsequent colorectal neoplasia. Dig Dis. 1996;41(7):1319-1326.
13 Boyapati SM, Bostick RM, McGlynn KA, et al. Calcium, vitamin D, and risk for colorectal adenoma: dependency on vitamin D receptor BsmI polymorphism and nonsteroidal anti-inflammatory drug use?. Cancer Epidemiol Biomarkers Prev. 2003;12(7):631-637. [pmid: 12869402].
14 Chan AT, Giovannucci EL, Schernhammer ES, et al. A prospective study of aspirin use and the risk for colorectal adenoma. Ann Intern Med. 2004;140(3):157-166. [pmid: 14757613].
15 Giovannucci E, Rimm EB, Stampfer MJ, et al. Aspirin use and the risk for colorectal cancer and adenoma in male health professionals. Ann Intern Med. 1994;121(4):241-246. [pmid: 8037405].
16 Greenberg ER, Baron JA, Freeman DH Jr. et al. Reduced risk of large-bowel adenomas among aspirin users. The Polyp Prevention Study Group. J Natl Cancer Inst. 1993;85(11):912-916. [pmid: 8492320].
17 Tangrea JA, Albert PS, Lanza E, et al. Non-steroidal anti-inflammatory drug use is associated with reduction in recurrence of advanced and non-advanced colorectal adenomas (United States). Cancer Causes Control. 2003;14(5):403-411. [pmid: 12946034].
18 Baron JA, Cole BF, Sandler RS, et al. A randomized trial of aspirin to prevent colorectal adenomas. N Engl J Med. 2003;348(10):891-899. [pmid: 12621133].
19 Benamouzig R, Deyra J, Martin A, et al. Daily soluble aspirin and prevention of colorectal adenoma recurrence: one-year results of the APACC trial. Gastroenterology. 2003;125(2):328-336. [pmid: 12891533].
20 Gann PH, Manson JE, Glynn RJ, et al. Low-dose aspirin and incidence of colorectal tumors in a randomized trial. J Natl Cancer Inst. 1993;85(15):1220-1224. [pmid: 8331682].
21 Ladenheim J, Garcia G, Titzer D, et al. Effect of sulindac on sporadic colonic polyps. Gastroenterology. 1995;108(4):1083-1087. [pmid: 7698575].
22 Garcia Rodriguez LA, Huerta-Alvarez C. Reduced risk of colorectal cancer among long-term users of aspirin and nonaspirin nonsteroidal antiinflammatory drugs. Epidemiology. 2001;12(1):88-93. [pmid: 11138826].
23 La Vecchia C, Negri E, Franceschi S, et al. Aspirin and colorectal cancer. Br J Cancer. 1997;76(5):675-677. [pmid: 9303370].
24 Muscat JE, Stellman SD, Wynder EL. Nonsteroidal antiinflammatory drugs and colorectal cancer. Cancer. 1994;74(7):1847-1854. [pmid: 8082089].
25 Kune GA, Kune S, Watson LF. Colorectal cancer risk, chronic illnesses, operations, and medications: case control results from the Melbourne Colorectal Cancer Study. Cancer Res. 1988;48(15):4399-4404. [pmid: 3390835].
26 Shaheen NJ, Silverman LM, Keku T, et al. Association between hemochromatosis (HFE) gene mutation carrier status and the risk of colon cancer. J Natl Cancer Inst. 2003;95(2):154-159. [pmid: 12529348].
27 Juarranz M, Calle-Puron ME, Gonzalez-Navarro A, et al. Physical exercise, use of Plantago ovata and aspirin, and reduced risk of colon cancer. Eur J Cancer Prev. 2002;11(5):465-472. [pmid: 12394244].
28 Coogan PF, Rosenberg L, Louik C, et al. NSAIDs and risk of colorectal cancer according to presence or absence of family history of the disease. Cancer Causes Control. 2000;11(3):249-255. [pmid: 10782659].
29 Collet JP, Sharpe C, Belzile E, et al. Colorectal cancer prevention by non-steroidal anti-inflammatory drugs: effects of dosage and timing. Br J Cancer. 1999;81(1):62-68. [pmid: 10487613].
30 Reeves MJ, Newcomb PA, Trentham-Dietz A, et al. Nonsteroidal anti-inflammatory drug use and protection against colorectal cancer in women. Cancer Epidemiol Biomarkers Prev. 1996;5(12):955-960. [pmid: 8959316].
31 Slattery ML, Samowitz W, Hoffman M, et al. Aspirin, NSAIDs, and colorectal cancer: Possible involvement in an insulin-related pathway. Cancer Epidemiol Biomarkers Prev. 2004;13(4):538-545. [pmid: 15066917].
32 Sturmer T, Glynn RJ, Lee IM, et al. Aspirin use and colorectal cancer: post-trial follow-up data from the Physicians' Health Study. Ann Intern Med. 1998;128(9):713-720. [pmid: 9556464].
33 Giovannucci E, Egan KM, Hunter DJ, et al. Aspirin and the risk of colorectal cancer in women. N Engl J Med. 1995;333(10):609-614. [pmid: 7637720].
34 Schreinemachers DM, Everson RB. Aspirin use and lung, colon, and breast cancer incidence in a prospective study. epi. 1994;5(2):138-146.
35 Thun MJ, Namboodiri MM, Heath CW Jr. Aspirin use and reduced risk of fatal colon cancer. N Engl J Med. 1991;325(23):1593-1596. [pmid: 1669840].
36 Lipworth L, Friis S, Blot WJ, et al. A population-based cohort study of mortality among users of ibuprofen in Denmark. Am J Ther. 2004;11(3):156-163. [pmid: 15133529].
37 Sorensen HT, Friis S, Norgard B, et al. Risk of cancer in a large cohort of nonaspirin NSAID users: a population-based study. Br J Cancer. 2003;88(11):1687-1692. [pmid: 12771981].
38 Friis S, Sorensen HT, McLaughlin JK, et al. A population-based cohort study of the risk of colorectal and other cancers among users of low-dose aspirin. Br J Cancer. 2003;88(5):684-688. [pmid: 12618874].
39 Smalley W, Ray WA, Daugherty J, et al. Use of nonsteroidal anti-inflammatory drugs and incidence of colorectal cancer: a population-based study. Arch Intern Med. 1999;159(2):161-166. [pmid: 9927099].
40 Paganini-Hill A. Aspirin and colorectal cancer: the Leisure World cohort revisited. Prev Med. 1995;24(2):113-115. [pmid: 7597009].
41 Rosenberg L, Louik C, Shapiro S. Nonsteroidal antiinflammatory drug use and reduced risk of large bowel carcinoma. Cancer. 1998;82(12):2326-2333. [pmid: 9635524].
42 Rosenberg L, Palmer JR, Zauber AG, et al. A hypothesis: nonsteroidal anti-inflammatory drugs reduce the incidence of large-bowel cancer. J Natl Cancer Inst. 1991;83(5):355-358. [pmid: 1759994].
43 Friedman GD, Coates AO, Potter JD, et al. Drugs and colon cancer. Pharmacoepidemiol Drug Saf. 1998;7(2):99-106. [pmid: 15073733].
44 Morimoto LM, Newcomb PA, Ulrich CM, et al. Risk factors for hyperplastic and adenomatous polyps: evidence for malignant potential?. Cancer Epidemiol Biomarkers Prev. 2002;11(10 Pt 1):1012-1018. [pmid: 12376501].
45 Gibbs WJ, Fugate SE, Vesta KS. Optimal antithrombotic management of anticoagulated patients with a history of myocardial infarction. [Review] [16 refs]. Cardiol Rev. 2004;12(6):327-333. [pmid: 15476572].
46 Hart RG, Halperin JL, McBride R, et al. Aspirin for the primary prevention of stroke and other major vascular events: meta-analysis and hypotheses. Arch Neurol. 2000;57(3):326-332. [pmid: 10714657].
47 Hayden M, Pignone M, Phillips C, et al. Aspirin for the primary prevention of cardiovascular events: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2002;136(2):161-172. [pmid: 11790072].
48 He J, Whelton PK, Vu B, et al. Aspirin and risk of hemorrhagic stroke: a meta-analysis of randomized controlled trials. JAMA. 1998;280(22):1930-1935. [pmid: 9851479].
49 Weisman SM, Graham DY. Evaluation of the benefits and risks of low-dose aspirin in the secondary prevention of cardiovascular and cerebrovascular events. Arch Intern Med. 2002;162(19):2197-2202. [pmid: 12390062].
50 Serebruany VL, Malinin AI, Eisert RM, et al. Risk of bleeding complications with antiplatelet agents: meta-analysis of 338,191 patients enrolled in 50 randomized controlled trials. Am J Hematol. 2004;75(1):40-47. [pmid: 14695631].
51 Lip GY, Felmeden DC. Antiplatelet agents and anticoagulants for hypertension. [Review][117 refs]. Cochrane Database Syst Rev 2004;(3):CD003186.
52 Derry S, Loke YK. Risk of gastrointestinal haemorrhage with long term use of aspirin: meta-analysis. BMJ. 2000;321(7270):1183-1187. [pmid: 11073508].
53 Garcia Rodriguez LA, Hernandez-Diaz S, de Abajo FJ. Association between aspirin and upper gastrointestinal complications: systematic review of epidemiologic studies. Br J Clin Pharmacol. 2001;52(5):563-571. [pmid: 11736865].
54 Tramer MR, Moore RA, Reynolds DJ, et al. Quantitative estimation of rare adverse events which follow a biological progression: a new model applied to chronic NSAID use. Pain. 2000;85(12):169-182. [pmid: 10692616].
55 Roderick PJ, Wilkes HC, Meade TW. The gastrointestinal toxicity of aspirin: an overview of randomised controlled trials. Br J Clin Pharmacol. 1993;35(3):219-226. [pmid: 8471398].
56 Huang JQ, Sridhar S, Hunt RH. Role of Helicobacter pylori infection and non-steroidal anti-inflammatory drugs in peptic-ulcer disease: a meta-analysis. Lancet. 2002;359(9300):14-22. [pmid: 11809181].
57 Ofman JJ, MacLean CH, Straus WL, et al. A metaanalysis of severe upper gastrointestinal complications of nonsteroidal antiinflammatory drugs. J Rheumatol. 2002;29(4):804-812. [pmid: 11950025].
58 Ofman JJ, MacLean CH, Straus WL, et al. Meta-analysis of dyspepsia and nonsteroidal antiinflammatory drugs. Arthritis Rheum. 2003;49(4):508-518. [pmid: 12910557].
59 Rostom, A., Dube, C., Jolicoeur, E., Boucher, M., and Joyce, J. Gastroduodenal ulcers associated with the use of non-steroidal anti-inflammatory drugs: a systematic review of preventative pharmacological interventions. Ottawa: CCOHTA, 2004. Technology Report Issue 38.
60 Hooper L, Brown TJ, Elliott R, et al. The effectiveness of five strategies for the prevention of gastrointestinal toxicity induced by non-steroidal anti-inflammatory drugs: systematic review. BMJ. 2004;329(7472):948. [pmid: 15475342].
61 Garner S, Fidan D, Frankish R et al. Celecoxib for rheumatoid arthritis. Cochrane Database Syst Rev 2002;(4):CD003831.
62 Deeks JJ, Smith LA, Bradley MD. Efficacy, tolerability, and upper gastrointestinal safety of celecoxib for treatment of osteoarthritis and rheumatoid arthritis: systematic review of randomised controlled trials. BMJ. 2002;325(7365):619. [pmid: 12242171].
63 Edwards JE, McQuay HJ, Moore RA. Efficacy and safety of valdecoxib for treatment of osteoarthritis and rheumatoid arthritis: systematic review of randomised controlled trials. [Review] [31 refs]. Pain. 2004;111(3):286-296. [pmid: 15363872].
64 Garner SE, Fidan DD, Frankish R et al. Rofecoxib for osteoarthritis. Cochrane Database Syst Rev 2005;(1):CD005115.
65 Garner SE, Fidan DD, Frankish RR et al. Rofecoxib for rheumatoid arthritis. Cochrane Database Syst Rev 2005;(1):CD003685.
66 Gomez CJ, Lubomirov HR, Carcas Sansuan AJ, et al. Outcome trials of COX-2 selective inhibitors: global safety evaluation does not promise benefits. Eur J Clin Pharmacol. 2003;59(2):169-175. [pmid: 12698301].
67 Mukherjee D, Nissen SE, Topol EJ. Risk of cardiovascular events associated with selective COX-2 inhibitors. JAMA. 2001;286(8):954-959. [pmid: 11509060].
68 Juni P, Nartey L, Reichenbach S, et al. Risk of cardiovascular events and rofecoxib: cumulative meta-analysis. Lancet. 2004;364(9450):2021-2029. [pmid: 15582059].
69 Ashcroft DM, Chapman SR, Clark WK, et al. Upper gastroduodenal ulceration in arthritis patients treated with celecoxib. Ann Pharmacother. 2001;35(78):829-834. [pmid: 11485128].
70 Goldstein JL, Eisen GM, Agrawal N, et al. Reduced incidence of upper gastrointestinal ulcer complications with the COX-2 selective inhibitor, valdecoxib. Aliment Pharmacol Ther. 2004;20(5):527-538. [pmid: 15339324].
71 Schoenfeld P. Gastrointestinal safety profile of meloxicam: a meta-analysis and systematic review of randomized controlled trials. Am J Med. 1999;107(6A):48S-54S. [pmid: 10628593].
72 Eisen GM, Goldstein JL, Hanna DB, et al. Meta-analysis: upper gastrointestinal tolerability of valdecoxib, a cyclooxygenase-2-specific inhibitor, compared with nonspecific nonsteroidal anti-inflammatory drugs among patients with osteoarthritis and rheumatoid arthritis. Aliment Pharmacol Ther. 2005;21(5):591-598. [pmid: 15740543].
73 Suleiman S, Rex DK, Sonnenberg A. Chemoprevention of colorectal cancer by aspirin: a cost-effectiveness analysis. Gastroenterology. 2002;122(1):78-84. [pmid: 11781283].
74 Ladabaum U, Chopra CL, Huang G, et al. Aspirin as an adjunct to screening for prevention of sporadic colorectal cancer. A cost-effectiveness analysis. Ann Intern Med. 2001;135(9):769-781. [pmid: 11694102].
75 Ladabaum U, Scheiman JM, Fendrick AM. Potential effect of cyclooxygenase-2 - Specific inhibitors on the prevention of colorectal cancer: A cost-effectiveness analysis. Am J Med. 2003;114(7):546-554. [pmid: 12753878].
76 Arguedas MR, Heudebert GR, Wilcox CM. Surveillance colonoscopy or chemoprevention with COX-2 inhibitors in average-risk post-polypectomy patients: a decision analysis. Aliment Pharmacol Ther. 2001;15(5):631-638. [pmid: 11328256].
77 Hur C, Simon LS, Gazelle GS. The cost-effectiveness of aspirin versus cyclooxygenase-2-selective inhibitors for colorectal carcinoma chemoprevention in healthy individuals. Cancer. 2004;101(1):189-197. [pmid: 15222006].