# Appendix 7. QUOROM flowchart

Key Questions 1, 2 and 4 (Efficacy and cost-effectiveness)

Key Question 3 (Harms)