# Appendix 2. Study Selection—Screening Forms

## Aspirin and NSAIDs for chemoprevention of colorectal cancer (CRC_NSAID)-SRS

### Screening questions: LEVEL 1 (Broad screening)

#### Inclusion Criteria

1 Does this citation refer to a potentially relevant study of ASA or any NSAIDs/Cox-2 Inhibitors for the prevention of polyps or colon cancer or related death? ([underlined: NOTE]: we are not interested in animal or tissue culture studies. Include FAP or Lynch or IBD for discussion only)
  YES NO CAN'T TELL
2 Please, check all that apply (non-consequential)
  a Refers also to harms (key question 3)
  b Is a systematic or narrative review
  c Is a cost-effectiveness analysis
  d IMPORTANT for Introduction/discussion
  e None of the above
  f Can't tell
3 Comment's box

### Screening questions: LEVEL 2 (Relevant Assessment)

#### Inclusion Criteria

1 Does this study include the following population: healthy adults (>18 years of age) with or without family history of sporadic CRC or a personal history of polyps (exclude: previous CRC, FAP, HNPCC, IBD)?
  YES NO CAN'T TELL
2 Does this study employ Aspirin or any class of NSAIDs (e.g., ibuprofen, diclofenac, naproxen, COX-2 Inh, etc.) as an intervention?
  YES NO CAN'T TELL
3 Does this intervention target the prevention of colorectal cancer or incidence of colorectal adenomatous polyps or its related mortality?
  YES NO CAN'T TELL
4 What is the study design? Select one: (a-e included for Data Abstraction/quality assessment) colorectal cancer
  a RCT
  b Non-RCT (controlled trial, non-randomized)
  c Prospective cohort study
  d Case-control study
  e Cost-effectiveness analysis
  f Systematic review
  g Narrative Review
  h Can't tell
  i None of the Above
5 I want this article for the report (discussion, introduction) (optional)
  YES NO
6 Comment's box

### Screening questions: LEVEL 3 (Level of evidence)

1 Does this report belong to the following Levels of Evidence (see below)?
  YES NO
2 Level of evidence of this report (select one):
  a RCT parallel design
  b RCT crossover design
  c RCT factorial design
  d Controlled clinical trial (non-RCT)
  e Multiple prospective cohorts
  f At least one prospective cohort and one retrospective cohort
  g Case-control
  h Cost-effectiveness analysis/Economic
  i None of the above

## Data abstraction form: General and by level of evidence

Instructions: Please answer each question. Selecting response options means clicking on them. A box presented with or without a request to select response options is asking you to provide specific information. When it is not reported (= NR), the question does not apply (= N/A), you cannot tell what it is (= CT), or you have no comment (= NC), type the relevant code in the text box. If the research report describes more than one study, answer in this eForm all the questions for the first reported study and the companion studies as if it were only one report.

1 Initials of reviewer: BOX
2 Reference identification # (Refid): BOX
3 Author, Year, Location (country(ies): BOX
4 Publication status (select one):
  a Journal publication
  b Cochrane review
  c Conference abstract/poster
  d Book
  e Book chapter
  f UpTodate
  g HTA/technical report
  h FDA website document
  i Other Internet document
  j Thesis
  k Unpublished document
  l Study sponsor's internal report
  m Other: BOX
5 If other included reports refer to this same study, provide the Refid(s): BOX
6 Setting(s) (select all):
  - Number of sites: BOX
  - Setting(s) (e.g., GI department, teaching hospital, etc): BOX
7 Funding source type (select all that apply) and specify:
  a Government
  b Industry
  c Private (non-industry)
  d Hospital
  e Other
  f Not reported
  g Can't tell
8 Population characteristics (select all):
  - Total # individuals screened/enrolled/completed (e.g. n=320/298/270): BOX
  - Mean Age (SD/SE; range) of all study participants (eg. 35 (20–55) y): BOX
  - % Males (full sample): BOX
  - Race/ethnicity (White (%), Black (%), etc): BOX
  - Weight (per arm/cohort): BOX
9 Eligibility criteria (select all ):
  - Inclusion criteria: BOX
  - Exclusion criteria: BOX
10 Study duration (select all):
  - Total study duration: BOX
  - Screening/wash out/intervention/follow-up periods (eg. 2 y/NR/1 y/4 y): BOX
11 Number of dropouts/withdrawals with reasons, per study arm/cohort: BOX
12 Comments BOX
  1 Please, click the design where is belongs:
    - [underlined: Randomized controlled trial/non-randomized controlled trial]
    - [underlined: Prospective Cohort study (multiple or single)]
    - [underlined: Case-control study]

### RCTs/Non-RCTs

2 Identify any problems with the research design (e.g., definition of placebo/control(s); inappropriateness of run-in and washout periods), or its implementation: BOX
3 Comments on notable differences between study arms/cohorts re Age, % males, Race/ethnic composition and/or weight of their participants at baseline (e.g. Arm 1 S > % males than Arm 2 or NS between arms): BOX
4 Risk Factors for CRC at baseline, specify proportion of each (select all that apply):
  a Average risk: BOX
  b Family history of colorectal cancer: BOX
  c Family history of polyps: BOX
  d Personal history of polyps: BOX
  e Other: BOX
  f None of the above
  g can't tell
5 Comments, including notable differences between study arms re each risk factor at baseline (eg. Arm 1 S > % family history of polyps than Arm 2): BOX
6 Concurrent and/or antecedent conditions at baseline (% per arm), including notable differences between arm/cohorts: BOX
7 Pre-study medications/treatments and dose, per arm (including NSAID, aspirin, GI protectors, supplements, vitamins, etc): BOX
8 Participants were enrolled according to which criterion (select one)?
  a Intention-to-treat (all randomized/enrolled)
  b Those receiving at least one dose
  c Those completing the study (i.e., with follow-up data)
  d Can't tell
  e Other: BOX
9 Was sample size calculated (Beta, alpha, one/two-sided?) (select one):
  YES NO CAN'T TELL
10 Comments about the statistical analysis (Power analysis, appropriateness of statistical method, etc): BOX
11 Cointerventions/other exposures: describe the medications/treatments/exposures allowed during the study period (drug, dose, etc): BOX
12 Describe the diagnosis method(s) of polyps/CRC (e.g., colonoscopy, surgery, etc): BOX
13 How were the intestinal polyps/CRC defined (including size, location and histology)? BOX
14 Describe the outcomes measured in this study (select all):
  a Primary: BOX
  b Secondary: BOX
15 Timing of outcome assessments and when, relative to start of intervention (eg, week 4): BOX
16 Which method(s) were used to assess the clinical outcomes (e.g., Flexible sigmoidoscopy, colonoscopy, barium enema, combination, other)? BOX
17 Number of arms included in this study (define) Note: in a cross-over trial, each different phase is considered an intervention arm): BOX
18 Study arm number 1 (select all):
  a Intervention type (e.g., drug or placebo): BOX
  b Brand/ manufacturer (if applicable): BOX
  c Dose / frequency / timing: BOX
  d Intervention length: BOX
  e number of participants enrolled/completed (eg, n=22/16) BOX
19 Study arm number 2 (select all) ([underlined: if there are no more arms/cohort GO to question 25])
  a Intervention type (e.g., drug or placebo): BOX
  b Brand/ manufacturer (if applicable): BOX
  c Dose / frequency / timing: BOX
  d Intervention length: BOX
  e number of participants enrolled/completed (eg, n=22/16) BOX
20 Study arm number 3 (select all) ([underlined: if there are no more arms/cohort GO to question 25])
  a Intervention type (e.g., drug or placebo): BOX
  b Brand/ manufacturer (if applicable): BOX
  c Dose / frequency / timing: BOX
  d Intervention length: BOX
  e number of participants enrolled/completed (eg, n=22/16) BOX
21 Study arm number 4 (select all) ([underlined: if there are no more arms/cohort GO to question 25])
  a Intervention type (e.g., drug or placebo): BOX
  b Brand/ manufacturer (if applicable): BOX
  c Dose / frequency / timing: BOX
  d Intervention length: BOX
  e number of participants enrolled/completed (eg, n=22/16) BOX
22 Adverse events/ side effects reported in the present study, per study arm/cohort (select all that apply):
  a GI toxicity: BOX
  b Renal: BOX
  c Hemorrhagic events: BOX
  d Cardiovascular: stroke BOX
  e CV: MI BOX
  f Hepatic: BOX
  g Death BOX
  h Hospitalization BOX
  i Other: BOX
  j Comments BOX
23 Outcome results (statistical significant difference only, e.g., NSAID group did S better than placebo group) (select all that apply): NOTE: ROW DATA WILL BE EXTRACTED IF METAANALYSIS IS FEASIBLE BY OUR STATISTICIAN NS = nonstatistically significant difference; S = statistically significant difference
  a Mortality (Overall) BOX
  b Mortality for CRC: BOX
  c Incidence of CRC: BOX
  d Stage of CRC: BOX
  e Incidence of any polyps: BOX
  f Incidence of advanced polyps: BOX
  g Number of polyps: BOX
  h Size of polyps: BOX
  i Other (defined by the author): BOX
24 Control for potential confounders/ covariates/ effect modifiers (If it was done, how and results): BOX
25 Comments BOX

### Prospective cohort studies (multiple or single)

26 Study population: (select all)
  - Name of cohort(s): BOX
  - Length of followup: BOX
27 Risk Factors for CRC at baseline, specify proportion of each (select all that apply):
  a Average risk: BOX
  b Family history of colorectal cancer: BOX
  c Family history of polyps: BOX
  d Personal history of polyps: BOX
  e Other: BOX
  f None of the above
  g can't tell
28 Comments, including notable differences between exposed vs. non-exposed re each risk factor at baseline (eg. exposed 1 S > % family history of polyps than non-exposed): BOX
29 Number and definition of exposures (types of NSAIDs/ASA considered): BOX
30 Ascertainment of exposure (e.g. questionnaire; frequency of data gathering): BOX
31 Cointerventions/other exposures: describe the medications/treatments/exposures allowed during the study period (drug, dose, etc): BOX
32 Comments on notable differences between exposed vs. non-exposed re Age, % males, Race/ethnic composition, and co-interventions: BOX
33 Describe the outcomes measured in this study (select all that apply):
  a Primary
    - Number of polyps
    - Number of CRCs
    - Mortality from CRC
    - Overall mortality
    - Other: BOX
  b dose or equivalent: BOX Secondary
    - Number of polyps
    - Number of CRCs
    - Mortality from CRC
    - Overall mortality
    - Other: BOX
34 Timing of outcome assessments and when, relative to start of intervention (eg, years of f/u): BOX
35 Describe the data source for outcome measure (e.g., colonoscopy, surgery, pathology records, mortality records): BOX
36 How were the intestinal polyps/CRC defined (including size, location and histology)? BOX
37 How were cases ascertained? (review of case records, pathology slides): BOX
38 Completeness of data (e.g. % subjects with incomplete records): BOX
39 Identify any problems with the research design (e.g., measure of exposure, case ascertainment, follow-up, study population), or its implementation: BOX
40 Non-exposed (select all that apply)
  a exposure type if any: BOX
  b Cumulative
  c Duration of f/u: BOX
  d number of participants enrolled/analyzed (eg, n=22/16) BOX
41 Exposed number 1
  a exposure type: BOX
  b Cumulative dose or equivalent: BOX
  c Duration of f/u: BOX
  d number of participants enrolled/analyzed (eg, n=22/16): BOX
42 Exposed number 2 ([underlined: if there are no more arms/cohort GO to question 48])
  a exposure type: BOX
  b Cumulative dose or equivalent: BOX
  c Duration of f/u: BOX
  d number of participants enrolled/analyzed (eg, n=22/16) BOX
43 Exposed number 3([underlined: if there are no more arms/cohort GO to question 48])
  a exposure type: BOX
  b Cumulative dose or equivalent: BOX
  c Duration of f/u: BOX
  d number of participants enrolled/analyzed (eg, n=22/16) BOX
44 Adverse events/ side effects reported in the present study, in exposed vs. non exposed (select all that apply):
  a GI toxicity: BOX
  b Renal: BOX
  c Hemorrhagic events: BOX
  d Cardiovascular: stroke BOX
  e CV: MI BOX
  f Hepatic: BOX
  g Death BOX
  h Hospitalization BOX
  i Other: BOX
  j Comments BOX
45 Outcome results (statistical significant difference only, e.g., exposed group did S better than non-exposed group) (select all that apply ): NOTE: ROW DATA WILL BE EXTRACTED IF METAANALYSIS IS FEASIBLE BY OUR STATISTICIAN NS = nonstatistically significant difference; S = statistically significant difference
  a Mortality (Overall) BOX
  b Mortality for CRC: BOX
  c Incidence of CRC: BOX
  d Stage of CRC: BOX
  e Incidence of any polyps: BOX
  f Incidence of advanced polyps: BOX
  g Number of polyps: BOX
  h Size of polyps: BOX
  i Other (defined by the author): BOX
46 Control for potential confounders/ covariates/ effect modifiers (If it was done, how and results): BOX
47 Comments about the statistical analysis (Power analysis, appropriateness of statistical method, etc): BOX
48 Comments BOX

### Case-control studies

49 Comments on notable differences between cases and controls re Age, % males, Race/ethnic composition and/or weight of their participants at baseline (e.g. cases S > % males than controls or NS between groups): BOX
50 Comments on notable differences between case and controls re Risk Factors for CRC (as %in cases and % in controls) (select all that apply): (if applicable)
  a Average risk: BOX
  b Family history of colorectal cancer: BOX
  c Family history of polyps: BOX
  d Personal history of polyps: BOX
  e Other: BOX
  f Not reported
  g Not applicable
51 Comments, including notable differences between cases and controls re each risk factor at baseline (eg. cases S > % family history of polyps than controls): BOX
52 Concurrent and/or antecedent conditions (% per group), including notable differences between cases and controls (if applicable): BOX
53 Number and definition of exposures (types of NSAIDs considered): BOX
54 Ascertainment of exposure (e.g. questionnaire, chart review): BOX
55 Co-interventions/other exposures: list other exposures that were also measured BOX
56 Comments on notable differences between cases and controls re co-interventions: BOX
57 Describe the diagnosis method(s) of polyps/CRC (e.g., colonoscopy, surgery, etc): BOX
58 How were the intestinal polyps/CRC defined (including size, location and histology)? BOX
59 Describe the outcomes measured in this study (select all that apply):
  a Primary
    - number of polyps
    - number of CRCs
    - mortality from CRC
    - overall mortality
    - NASID exposure
    - Other: BOX
  b Secondary
    - number of polyps
    - number of CRCs
    - mortality from CRC
    - overall mortality
    - NSAID exposure
    - Other: BOX
60 Which method(s) were used to assess the clinical outcomes (e.g., Flexible sigmoidoscopy, colonoscopy, barium enema, combination, other)? BOX
61 Cases (select all)
  - Source of recruitment of cases (eg database, part of a cohort, clinic attendance): BOX
  - Definition of cases: (eg. Incident adenomatous polyp, incident CRC etc ): BOX
  - Ascertainment of cases (eg, Review of pathology, chart review, etc) BOX
  - Number of participants enrolled/analyzed (eg, n=22/16) BOX
62 Controls 1
  - Source of recruitment of controls (e.g. pts attending a clinic): BOX
  - Definition of controls (eg. absence of CRC or polyp, etc): BOX
  - Number of participants enrolled/analyzed (eg, n=22/16) BOX
63 Controls 2 (if applicable)
  - Source of recruitment of controls (e.g. pts attending a clinic): BOX
  - Definition of controls (eg. absence of CRC or polyp, etc): BOX
  - Number of participants enrolled/analyzed (eg, n=22/16) BOX
64 Adverse events/ side effects reported in the present study, per study arm/cohort (select all that apply):
  a GI toxicity: BOX
  b Renal: BOX
  c Hemorrhagic events: BOX
  d Cardiovascular: stroke BOX
  e CV: MI BOX
  f Hepatic: BOX
  g Death BOX
  h Hospitalization BOX
  i Other: BOX
  j Comments BOX
65 Identify any problems with the research design (e.g., definition of case/control(s)), or its implementation: BOX
66 Outcome results (as OR according to NSAID exposure) (select all that apply): NOTE: ROW DATA WILL BE EXTRACTED IF METAANALYSIS IS FEASIBLE BY OUR STATISTICIAN NS = nonstatistically significant difference; S = statistically significant difference
  a Mortality (Overall) BOX
  b Mortality for CRC: BOX
  c Incidence of CRC: BOX
  d Stage of CRC: BOX
  e Incidence of any polyps: BOX
  f Incidence of advanced polyps: BOX
  g Other (defined by the author): BOX
67 Control for potential confounders/ covariates/ effect modifiers (If it was done, how and results): BOX
68 Comments about the statistical analysis (Power analysis, appropriateness of statistical method, etc): BOX
69 Comments BOX

### Screening Questions For Key question 3 (harms): LEVEL 1 (Broad screening)

1 Is this a systematic review (of RCTs or cohort studies or case-control) that addresses gastrointestinal and/or cardiovascular and/or renal harms due to the chronic use (at least 4 weeks) of Aspirin or any NSAID (including COX-2 Inhibitors) on any human adult (> 18 years old) population? (only in English) (Reviews about efficacy of a drug are also included)
  YES NO CAN'T TELL
2 I want this article for Introduction-Discussion
  YES NO CAN'T TELL
3 Comments BOX

### Screening Questions For Key question 3 (harms): LEVEL 2 (Relevance assessment)

1 Is this a systematic review (of RCTs or cohort studies or case-control) that addresses gastrointestinal and/or cardiovascular and/or renal harms due to the chronic use (at least 4 weeks) of Aspirin or any NSAID (including COX-2 Inhibitors) on any human adult (> 18 years old) population? (only in English (Reviews about efficacy of a drug are also included)
  YES NO CAN'T TELL
2 Does this review report on at least one the following endpoints:
  - GI: endoscopic ulcers, clinical ulcers (POB & PUB), GI symptoms (i.e., hemorrhage, pain, etc), death
  - CV: Hypertension, CHF, edema, MI, stroke, death
  - Renal: Renal failure (CFR, ARF), dialysis, increase in creatinine
3 I want this article for Introduction-Discussion
  YES NO CAN'T TELL
4 I want to contact the author for more info
  YES NO
5 Comments BOX

## Data abstraction form: Key question 3 (harms)

Instructions: Please answer each question . Selecting response options means clicking on them. A box presented with or without a request to select response options is asking you to provide specific information. When it is not reported (= NR), the question does not apply (= N/A), you cannot tell what it is (= CT), or you have no comment (= NC), type the relevant code in the text box. If the research report describes more than one study, answer in this eForm all the questions for the first reported study while at the same time letting the review manager know that another data abstraction form is required.

1 All. Initials of reviewer: BOX
2 All. Reference identification # (Refid): BOX
3 All. Author, Year: BOX
5 General. Publication status (select one):
  - Journal publication
  - Cochrane review
  - Conference abstract/poster
  - Book
  - Book chapter
  - UpTodate
  - HTA/technical report
  - FDA website document
  - Other Internet document
  - Thesis
  - Unpublished document
  - Study sponsor's internal report
  - Other BOX
6 All. If other included reports refer to this same study, provide the Refid(s): BOX
7 Title: was this report identified as a meta-analysis [or systematic review]? YES NO
8 Funding source type (select all that apply), specify: BOX
  - Government
  - Industry
  - Private (non-industry)
  - Hospital
  - Other BOX
  - Not reported
  - Can't tell
9 Is the objective of the review (select all that apply):
  - Efficacy of ASA/NSAID
  - Harms of ASA/NSAID
  - Both (efficacy and harms)
  - Other: BOX
10 Methodology (select all):
  - Searching method (information sources: databases [number], registers, personal files, gray literature, etc): BOX
  - Range of years considered in the search (e.g., 1966-2000): BOX
  - Language restriction (e.g., only English): BOX
11 Selection process (select all):
  - Inclusion criteria: population: BOX
  - Inclusion criteria: Intervention: BOX
  - Inclusion criteria: Outcomes: BOX
  - Inclusion criteria: Study design: BOX
  - Exclusion criteria: BOX
12 Comments on the quantitative data synthesis protocol (select all)
  - principal measures of effect [RR, OR, etc]: BOX
  - method combining results: BOX
  - handling missing data (contact authors?): BOX
  - how statistical heterogeneity was assessed (sensitivity analysis): BOX
  - publication bias assessed: BOX
13 Did the authors use at least 2 independent reviewers during the screening process? YES NO CAN'T TELL
14 Trial Flow (select all):
  - n citations screened at level 1: BOX
  - n reports retrieved for relevance assessment (hard copy): BOX
  - n reports included in the SR: BOX
  - n unique studies included in SR: BOX
  - n unique studies or reports included in meta-analysis (if applicable): BOX
15 Quality assessment (describe which score system was used for each study design, eg, Jadad score, etc): BOX
16 Were the study characteristics of each trial described or tabulated?
  YES NO CAN'T TELL
17 Study characteristics (select all):
  - Countries where trials were conducted: BOX
  - Sample size (total, range of sample sizes per study): BOX
  - Mean-median age or range of mean ages (all participants): BOX
  - Intervention(s) (name of drug, dose): BOX
  - Comparators (placebo, other drug): BOX
  - Duration of intervention (mean, range): BOX
  - Follow-up period (mean, range): BOX
18 Results GI adverse events (select all that apply):
  - POB (perforation/obstruction bleed): BOX
  - PUB (or symptomatic ulcer): BOX
  - Endoscopic ulcers: BOX
  - Dyspepsia: BOX
  - Abdominal pain: BOX
  - Nausea: BOX
  - Anemia/iron deficiency: BOX
  - Occult GI blood loss: BOX
  - Death due to GI adverse events: BOX
  - Other (defined by authors): BOX
  - None of the above
19 Results CV events (select all that apply):
  - Hypertension: BOX
  - CHF: BOX
  - Edema: BOX
  - MI: BOX
  - Stroke/TIA: BOX
  - Death due to CV events: BOX
  - Other (defined by authors): BOX
  - None of the above
20 Results Renal events (select all that apply):
  - Chronic renal failure (CRF): BOX
  - Acute renal failure (ARF): BOX
  - Dialysis: BOX
  - Increase in creatinine: BOX
  - Death due to Renal events: BOX
  - Other (defined by authors): BOX
  - None of the above
21 Results (select all that apply):
  - Mortality due to AE (general): BOX
  - Other (defined by authors): BOX
  - None of the above
22 If meta-analysis was done on harms, please describe the following information (select all):
  - Outcome 1 analyzed (with result): BOX
  - Outcome 2 analyzed (with result): BOX
  - Outcome 3 analyzed (with result): BOX
  - Outcome 4 analyzed (with result): BOX
  - Other outcomes and results: BOX
  - None of the above
23 Were the number and/or reasons for dropouts/withdrawals due to harms reported in the Systematic review (across the included studies)? YES NO Can't Tell
24 Was the author contacted by you or other members of the NSAID team re more information (raw data)? YES NO
25 Quality assessment results (mean score, by study design): BOX
26 Comment's BOX