# Appendix 1. Search strategies

## Key questions 1 and 2 (efficacy)

1 exp Anti-Inflammatory Agents, Non-Steroidal/
2 exp Cyclooxygenase Inhibitors/
3 Aminopyrine.ti,ab,rw.
4 Amodiaquine.ti,ab,rw.
5 Ampyrone.ti,ab,rw.
6 Antipyrine.ti,ab,rw.
7 Apazone.ti,ab,rw.
8 Aspirin.ti,ab,rw.
9 Bromelains.ti,ab,rw.
10 BW-755C.ti,ab,rw.
11 Celecoxib.ti,ab,rw.
12 Clofazimine.ti,ab,rw.
13 Clonixin.ti,ab,rw.
14 Curcumin.ti,ab,rw.
15 Dapsone.ti,ab,rw.
16 Diclofenac.ti,ab,rw.
17 Diflunisal.ti,ab,rw.
18 Dipyrone.ti,ab,rw.
19 Epirizole.ti,ab,rw.
20 Etodolac.ti,ab,rw.
21 Etoricoxib.ti,ab,rw.
22 Fenoprofen.ti,ab,rw.
23 Flurbiprofen.ti,ab,rw.
24 Glycyrrhizic Acid.ti,ab,rw.
25 Ibuprofen.ti,ab,rw.
26 Indomethacin.ti,ab,rw.
27 Indoprofen.ti,ab,rw.
28 Ketoprofen.ti,ab,rw.
29 Ketorolac.ti,ab,rw.
30 Lumiracoxib.ti,ab,rw.
31 Meclofenamic Acid.ti,ab,rw.
32 Mefenamic Acid.ti,ab,rw.
33 Mesalamine.ti,ab,rw.
34 Naproxen.ti,ab,rw.
35 Niflumic Acid.ti,ab,rw.
36 Nordihydroguaiaretic Acid.ti,ab,rw.
37 Oxyphenbutazone.ti,ab,rw.
38 Parecoxib.ti,ab,rw.
39 Pentosan Sulfuric Polyester.ti,ab,rw.
40 Phenylbutazone.ti,ab,rw.
41 Piroxicam.ti,ab,rw.
42 Prenazone.ti,ab,rw.
43 Salicylate$.ti,ab,rw.
44 Sulfasalazine.ti,ab,rw.
45 Sulindac.ti,ab,rw.
46 Suprofen.ti,ab,rw.
47 Tolmetin.ti,ab,rw.
48 Valdecoxib.ti,ab,rw.
49 Meloxicam.ti,ab,rw.
50 Nabumetone.ti,ab,rw.
51 Choline magnesium trisalicylate.ti,ab,rw.
52 Rofecoxib.ti,ab,rw.
53 or/1–52
54 Chemoprevention/
55 (prevention or prevent or chemoprevent$ or chemoprophyl$).ti.
56 54 or 55
57 53 or 56
58 exp Colorectal Neoplasms/
59 exp Intestinal Polyps/
60 exp Adenomatous Polyps/
61 (colorectal or colon or colonic or rectal or rectum or rectosigmoid or adenomat$).mp.
62 (cancer$ or carcinoma$ or adenocarcinoma$ or malignan$ or tumor$ or tumour$ or neoplasm$ or polyp$).mp.
63 61 and 62
64 or/58–60,63
65 57 and 64
66 exp Case-Control Studies/
67 exp cohort studies/
68 Cross-sectional studies/
69 exp Epidemiologic Studies/
70 ((cohort or incidence or prospective) adj2 (stud$ or analys$)).mp.
71 (case adj (control$ or base or comparison or referent)).mp.
72 ((Follow up or followup) adj (study or studies)).tw.
73 (observational adj (study or studies)).tw.
74 Longitudinal.tw.
75 Retrospective.tw.
76 Cross sectional.tw.
77 or/66–76
78 RANDOMIZED CONTROLLED TRIAL.pt.
79 CONTROLLED CLINICAL TRIAL.pt.
80 RANDOMIZED CONTROLLED TRIALS.sh.
81 RANDOM ALLOCATION.sh.
82 DOUBLE BLIND METHOD.sh.
83 SINGLE-BLIND METHOD.sh.
84 or/78–83
85 (ANIMALS not HUMAN).sh.
86 84 not 85
87 CLINICAL TRIAL.pt.
88 exp CLINICAL TRIALS/
89 (clin$ adj25 trial$).ti,ab.
90 ((singl$ or doubl$ or trebl$ or tripl$) adj25 (blind$ or mask$)).ti,ab.
91 PLACEBOS.sh.
92 placebo$.ti,ab.
93 random$.ti,ab.
94 versus.tw.
95 RESEARCH DESIGN.sh.
96 or/87–95
97 96 not 85
98 97 not 86
99 86 or 98
100 77 or 99
101 100 and 65
102 limit 101 to english language
103 102 not (ANIMALS not HUMAN).sh.

#1 (colorectal neoplasms[majr] AND human[mh] AND english[la]) OR ((colorectal[ti] OR colon[ti] OR colonic[ti] OR rectal[ti] OR rectum[ti] OR rectosigmoid[ti]) AND (cancer*[ti] OR carcinoma*[ti] OR adenocarcinoma*[ti] OR malignan*[ti] OR tumor*[ti] OR tumour*[ti] OR neoplasm*[ti]))

#2 non-steroidal anti inflammatory drugs or nsaids or nsaid or cox-2 inhibitor or cox 2 inhibitor or cyclooxygenase

#3 #1 AND #2 not (medline[sb] or in process[sb] or pubstatusaheadofprint) Limits: English, Cancer

## Harms (Key question 3)

1 (ae or ct or to).fs.
2 (risk$ or harm$).mp.
3 (adverse event$ or (Adverse adj2 reaction$)).mp.
4 (ADR or SAE).mp.
5 safety.mp.
6 (side effect$ or toxic$).mp.
7 or/1–6
8 exp Anti-Inflammatory Agents, Non-Steroidal/
9 exp Cyclooxygenase Inhibitors/
10 Aminopyrine.ti,ab,rw.
11 Amodiaquine.ti,ab,rw.
12 Ampyrone.ti,ab,rw.
13 Antipyrine.ti,ab,rw.
14 Apazone.ti,ab,rw.
15 Aspirin.ti,ab,rw.
16 Bromelains.ti,ab,rw.
17 BW-755C.ti,ab,rw.
18 Celecoxib.ti,ab,rw.
19 Clofazimine.ti,ab,rw.
20 Clonixin.ti,ab,rw.
21 Curcumin.ti,ab,rw.
22 Dapsone.ti,ab,rw.
23 Diclofenac.ti,ab,rw.
24 Diflunisal.ti,ab,rw.
25 Dipyrone.ti,ab,rw.
26 Epirizole.ti,ab,rw.
27 Etodolac.ti,ab,rw.
28 Etoricoxib.ti,ab,rw.
29 Fenoprofen.ti,ab,rw.
30 Flurbiprofen.ti,ab,rw.
31 Glycyrrhizic Acid.ti,ab,rw.
32 Ibuprofen.ti,ab,rw.
33 Indomethacin.ti,ab,rw.
34 Indoprofen.ti,ab,rw.
35 Ketoprofen.ti,ab,rw.
36 Ketorolac.ti,ab,rw.
37 Lumiracoxib.ti,ab,rw.
38 Meclofenamic Acid.ti,ab,rw.
39 Mefenamic Acid.ti,ab,rw.
40 Mesalamine.ti,ab,rw.
41 Naproxen.ti,ab,rw.
42 Niflumic Acid.ti,ab,rw.
43 Nordihydroguaiaretic Acid.ti,ab,rw.
44 Oxyphenbutazone.ti,ab,rw.
45 Parecoxib.ti,ab,rw.
46 Pentosan Sulfuric Polyester.ti,ab,rw.
47 Phenylbutazone.ti,ab,rw.
48 Piroxicam.ti,ab,rw.
49 Prenazone.ti,ab,rw.
50 Salicylate$.ti,ab,rw.
51 Sulfasalazine.ti,ab,rw.
52 Sulindac.ti,ab,rw.
53 Suprofen.ti,ab,rw.
54 Tolmetin.ti,ab,rw.
55 Valdecoxib.ti,ab,rw.
56 Meloxicam.ti,ab,rw.
57 Nabumetone.ti,ab,rw.
58 Choline magnesium trisalicylate.ti,ab,rw.
59 Rofecoxib.ti,ab,rw.
60 or/8–59
61 limit 60 to systematic reviews
62 limit 61 to english language
63 7 and 62
64 63 and (2003$ or 2004$).ed.

## Cost-effectiveness analysis (Key question 4)

1 exp Anti-Inflammatory Agents, Non-Steroidal/
2 exp Cyclooxygenase Inhibitors/
3 Aminopyrine.ti,ab,rw.
4 Amodiaquine.ti,ab,rw.
5 Ampyrone.ti,ab,rw.
6 Antipyrine.ti,ab,rw.
7 Apazone.ti,ab,rw.
8 Aspirin.ti,ab,rw.
9 Bromelains.ti,ab,rw.
10 BW-755C.ti,ab,rw.
11 Celecoxib.ti,ab,rw.
12 Clofazimine.ti,ab,rw.
13 Clonixin.ti,ab,rw.
14 Curcumin.ti,ab,rw.
15 Dapsone.ti,ab,rw.
16 Diclofenac.ti,ab,rw.
17 Diflunisal.ti,ab,rw.
18 Dipyrone.ti,ab,rw.
19 Epirizole.ti,ab,rw.
20 Etodolac.ti,ab,rw.
21 Etoricoxib.ti,ab,rw.
22 Fenoprofen.ti,ab,rw.
23 Flurbiprofen.ti,ab,rw.
24 Glycyrrhizic Acid.ti,ab,rw.
25 Ibuprofen.ti,ab,rw.
26 Indomethacin.ti,ab,rw.
27 Indoprofen.ti,ab,rw.
28 Ketoprofen.ti,ab,rw.
29 Ketorolac.ti,ab,rw.
30 Lumiracoxib.ti,ab,rw.
31 Meclofenamic Acid.ti,ab,rw.
32 Mefenamic Acid.ti,ab,rw.
33 Mesalamine.ti,ab,rw.
34 Naproxen.ti,ab,rw.
35 Niflumic Acid.ti,ab,rw.
36 Nordihydroguaiaretic Acid.ti,ab,rw.
37 Oxyphenbutazone.ti,ab,rw.
38 Parecoxib.ti,ab,rw.
39 Pentosan Sulfuric Polyester.ti,ab,rw.
40 Phenylbutazone.ti,ab,rw.
41 Piroxicam.ti,ab,rw.
42 Prenazone.ti,ab,rw.
43 Salicylate$.ti,ab,rw.
44 Sulfasalazine.ti,ab,rw.
45 Sulindac.ti,ab,rw.
46 Suprofen.ti,ab,rw.
47 Tolmetin.ti,ab,rw.
48 Valdecoxib.ti,ab,rw.
49 Meloxicam.ti,ab,rw.
50 Nabumetone.ti,ab,rw.
51 Choline magnesium trisalicylate.ti,ab,rw.
52 Rofecoxib.ti,ab,rw.
53 or/1–52
54 Chemoprevention/
55 (prevention or prevent or chemoprevent$ or chemoprophyl$).ti.
56 54 or 55
57 53 or 56
58 exp Colorectal Neoplasms/
59 exp Intestinal Polyps/
60 exp Adenomatous Polyps/
61 (colorectal or colon or colonic or rectal or rectum or rectosigmoid or adenomat$).mp.
62 (cancer$ or carcinoma$ or adenocarcinoma$ or malignan$ or tumor$ or tumour$ or neoplasm$ or polyp$).mp.
63 61 and 62
64 or/58–60,63
65 57 and 64
66 exp Case-Control Studies/
67 exp cohort studies/
68 Cross-sectional studies/
69 exp Epidemiologic Studies/
70 ((cohort or incidence or prospective) adj2 (stud$ or analys$)).mp.
71 (case adj (control$ or base or comparison or referent)).mp.
72 ((Follow up or followup) adj (study or studies)).tw.
73 (observational adj (study or studies)).tw.
74 Longitudinal.tw.
75 Retrospective.tw.
76 Cross sectional.tw.
77 or/66–76
78 RANDOMIZED CONTROLLED TRIAL.pt.
79 CONTROLLED CLINICAL TRIAL.pt.
80 RANDOMIZED CONTROLLED TRIALS.sh.
81 RANDOM ALLOCATION.sh.
82 DOUBLE BLIND METHOD.sh.
83 SINGLE-BLIND METHOD.sh.
84 or/78–83
85 (ANIMALS not HUMAN).sh.
86 84 not 85
87 CLINICAL TRIAL.pt.
88 exp CLINICAL TRIALS/
89 (clin$ adj25 trial$).ti,ab.
90 ((singl$ or doubl$ or trebl$ or tripl$) adj25 (blind$ or mask$)).ti,ab.
91 PLACEBOS.sh.
92 placebo$.ti,ab.
93 random$.ti,ab.
94 versus.tw.
95 RESEARCH DESIGN.sh.
96 or/87–95
97 96 not 85
98 97 not 86
99 86 or 98
100 77 or 99
101 100 and 65
102 limit 101 to english language
103 102 not (ANIMALS not HUMAN).sh.
104 limit 65 to english language
105 104 not (ANIMALS not HUMAN).sh.
106 ec.fs.
107 105 and 106
108 limit 105 to “economics (sensitivity)”
109 107 or 108
110 109 not 103