# References

1 Jemal A, Tiwari RC, Murray T, et al. Cancer statistics, 2004. CA Cancer J Clin. 2004;54(1):8-29. [pmid: 14974761].
2 Hayden M, Pignone M, Phillips C, et al. Aspirin for the primary prevention of cardiovascular events: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2002;136(2):161-172. [pmid: 11790072].
3 Trends in screening for colorectal cancer—United States, 1997 and 1999. MMWR Morb Mortal Wkly Rep 2001; 50(9):162–166.
4 From the Centers for Disease Control and Prevention. Trends in screening for colorectal cancer—United States, 1997 and 1999. JAMA 2001; 285(12):1570–1571.
5 Colorectal cancer test use among persons aged ≥50 years—United States, 2001. MMWR Morb Mortal Wkly Rep 2003; 52(10):193–196.
6 Seeff LC, Nadel MR, Klabunde CN, et al. Patterns and predictors of colorectal cancer test use in the adult U.S. population. Cancer. 2004;100(10):2093-2103. [pmid: 15139050].
7 Health Canada. Advisory Committee Briefing Document Celecoxib Valdecoxib Cardiovascular Safety. Available at: http://www.hc-sc.gc.ca/hpfb-dgpsa/tpd-dpt/pdf/briefing_document_12_01_2005.pdf 2005.
8 Food and Drug Administration. Arthritis & Drug Safety and Risk Management Advisory Committee Briefing Package. Available at: http://www.fda.gov/ohrms/dockets/ac/05/briefing/2005-4090b1-01.htm 2005.
9 Thiis-Evensen E, Hoff GS, Sauar J, et al. Population-based surveillance by colonoscopy: effect on the incidence of colorectal cancer. Telemark Polyp Study I. Scand J Gastroenterol. 1999;34(4):414-420. [pmid: 10365903].
10 Rostom, A., Dube, C., Jolicoeur, E., Boucher, M., and Joyce, J. Gastroduodenal ulcers associated with the use of non-steroidal anti-inflammatory drugs: a systematic review of preventative pharmacological interventions. Ottawa, Canada: CCOHTA, 2004. Technology Report Issue 38.
11 Rostom A, Dube C, Wells G et al. Prevention of NSAID-induced gastroduodenal ulcers. Cochrane Database Syst Rev 2002;(4):CD002296.
12 Asano TK, McLeod RS. Non steroidal anti-inflammatory drugs (NSAID) and Aspirin for preventing colorectal adenomas and carcinomas. Cochrane Database Syst Rev 2004;(2):CD004079.
13 Rostom A, Dube C, Wells G et al. Prevention of NSAID-induced gastroduodenal ulcers. Cochrane Database Syst Rev 2002;(4):CD002296.
14 Asano TK, McLeod RS. Non steroidal anti-inflammatory drugs (NSAID) and Aspirin for preventing colorectal adenomas and carcinomas. Cochrane Database Syst Rev 2004;(2):CD004079.
15 Chan AT, Tranah GJ, Giovannucci EL, et al. A prospective study of genetic polymorphisms in the cytochrome P-450 2C9 enzyme and the risk for distal colorectal adenoma. Clin Gastroenterol Hepatol. 2004;2(8):704-712. [pmid: 15290664].
16 Chan AT, Tranah GJ, Giovannucci EL, et al. Genetic variants in the UGT1A6 enzyme, aspirin use, and the risk of colorectal adenoma. J Natl Cancer Inst. 2005;97(6):457-460. [pmid: 15770010].
17 Hartman TJ, Albert PS, Snyder K, et al. The association of calcium and vitamin D with risk of colorectal adenomas. J Nutr. 2005;135(2):252-259. [pmid: 15671222].
18 Thun MJ, Namboodiri MM, Calle EE, et al. Aspirin use and risk of fatal cancer. Cancer Res. 1993;53(6):1322-1327. [pmid: 8443812].
19 Thun MJ, Calle EE, Namboodiri MM, et al. Risk factors for fatal colon cancer in a large prospective study. J Natl Cancer Inst. 1992;84(19):1491-1500. [pmid: 1433333].
20 Boyapati SM, Bostick RM, McGlynn KA, et al. Calcium, vitamin D, and risk for colorectal adenoma: dependency on vitamin D receptor BsmI polymorphism and nonsteroidal anti-inflammatory drug use?. Cancer Epidemiol Biomarkers Prev. 2003;12(7):631-637. [pmid: 12869402].
21 Benamouzig R, Yoon H, Little J, et al. APACC, a French prospective study on aspirin efficacy in reducing colorectal adenoma recurrence: design and baseline findings. Eur J Cancer Prev. 2001;10(4):327-335. [pmid: 11535875].
22 Rosenberg L, Palmer JR, Zauber AG, et al. A hypothesis: nonsteroidal anti-inflammatory drugs reduce the incidence of large-bowel cancer. J Natl Cancer Inst. 1991;83(5):355-358. [pmid: 1759994].
23 Rosenberg L, Louik C, Shapiro S. Nonsteroidal antiinflammatory drug use and reduced risk of large bowel carcinoma. Cancer. 1998;82(12):2326-2333. [pmid: 9635524].
24 Freedman AN, Michalek AM, Weiss HA, et al. Aspirin use and p53 expression in colorectal cancer. Cancer Detect Prev. 1998;22(3):213-218. [pmid: 9618042].
25 Peleg II, Maibach HT, Brown SH, et al. Aspirin and nonsteroidal anti-inflammatory drug use and the risk of subsequent colorectal cancer. Arch Intern Med. 1994;154(4):394-399. [pmid: 8117171].
26 Bigler J, Whitton J, Lampe JW, et al. CYP2C9 and UGT1A6 genotypes modulate the protective effect of aspirin on colon adenoma risk. Cancer Res. 2001;61(9):3566-3569. [pmid: 11325819].
27 Ulrich CM, Whitton J, Yu JH, et al. PTGS2 (COX-2) -765G > C promoter variant reduces risk of colorectal adenoma among nonusers of nonsteroidal anti-inflammatory drugs. Cancer Epidemiol Biomarkers Prev. 2005;14(3):616-619. [pmid: 15767339].
28 Muscat JE, Stellman SD, Wynder EL. Analgesic use and colorectal cancer. Prev Med. 1995;24(2):110-112. [pmid: 7597008].
29 Paganini-Hill A, Chao A, Ross RK, et al. Aspirin use and chronic diseases: a cohort study of the elderly. BMJ. 1989;299(6710):1247-1250. [pmid: 2513898].
30 Paganini-Hill A, Hsu G, Ross RK, et al. Aspirin use and incidence of large-bowel cancer in a California retirement community. J Natl Cancer Inst. 1991;83(16):1182-1183. [pmid: 1886151].
31 Camp NJ, Slattery ML. Classification tree analysis: a statistical tool to investigate risk factor interactions with an example for colon cancer (United States). Cancer Causes Control. 2002;13(9):813-823. [pmid: 12462546].
32 Murtaugh MA, Ma K-N, Caan BJ, et al. Association of fluids from beverages with risk of rectal cancer. Nutr Cancer. 2004;49(1):25-31. [pmid: 15456632].
33 Friedman GD, Coates AO, Potter JD, et al. Drugs and colon cancer. Pharmacoepidemiol Drug Saf. 1998;7(2):99-106. [pmid: 15073733].
34 Meier CR, Schmitz S, Jick H. Association between acetaminophen or nonsteroidal antiinflammatory drugs and risk of developing ovarian, breast, or colon cancer. Pharmacotherapy. 2002;22(3):303-309. [pmid: 11898889].
35 Langman MJ, Cheng KK, Gilman EA, et al. Effect of anti-inflammatory drugs on overall risk of common cancer: case-control study in general practice research database. BMJ. 2000;320(7250):1642-1646. [pmid: 10856067].
36 Garcia Rodriguez LA, Huerta-Alvarez C. Reduced risk of colorectal cancer among long-term users of aspirin and nonaspirin nonsteroidal antiinflammatory drugs. Epidemiology. 2001;12(1):88-93. [pmid: 11138826].
37 Garcia Rodriguez LA, Huerta-Alvarez C. Reduced incidence of colorectal adenoma among long-term users of nonsteroidal antiinflammatory drugs: a pooled analysis of published studies and a new population-based study. Epidemiology. 2000;11(4):376-381. [pmid: 10874542].
38 Rahme E, Barkun AN, Toubouti Y, et al. The cyclooxygenase-2-selective inhibitors rofecoxib and celecoxib prevent colorectal neoplasia occurrence and recurrence. Gastroenterology. 2003;125(2):404-412. [pmid: 12891542].
39 Chan AT, Giovannucci EL, Schernhammer ES, et al. A prospective study of aspirin use and the risk for colorectal adenoma. Ann Intern Med. 2004;140(3):157-166. [pmid: 14757613].
40 Ladabaum U, Chopra CL, Huang G, et al. Aspirin as an adjunct to screening for prevention of sporadic colorectal cancer. A cost-effectiveness analysis. Ann Intern Med. 2001;135(9):769-781. [pmid: 11694102].
41 Martinez ME, McPherson RS, Levin B, et al. Aspirin and other nonsteroidal anti-inflammatory drugs and risk of colorectal adenomatous polyps among endoscoped individuals. Cancer Epidemiol Biomarkers Prev. 1995;4(7):703-707. [pmid: 8672985].
42 Giovannucci E, Rimm EB, Stampfer MJ, et al. Aspirin use and the risk for colorectal cancer and adenoma in male health professionals. Ann Intern Med. 1994;121(4):241-246. [pmid: 8037405].
43 Smalley W, Ray WA, Daugherty J, et al. Use of nonsteroidal anti-inflammatory drugs and incidence of colorectal cancer: a population-based study. Arch Intern Med. 1999;159(2):161-166. [pmid: 9927099].
44 Kahi CJ, Imperiale TF. Do aspirin and nonsteroidal anti-inflammatory drugs cause false-positive fecal occult blood test results? A prospective study in a cohort of veterans. Am J Med. 2004;117(11):837-841. [pmid: 15589487].
45 Thun MJ, Namboodiri MM, Heath CW Jr. Aspirin use and reduced risk of fatal colon cancer. N Engl J Med. 1991;325(23):1593-1596. [pmid: 1669840].
46 Lipworth L, Friis S, Blot WJ, et al. A population-based cohort study of mortality among users of ibuprofen in Denmark. Am J Ther. 2004;11(3):156-163. [pmid: 15133529].
47 Gann PH, Manson JE, Glynn RJ, et al. Low-dose aspirin and incidence of colorectal tumors in a randomized trial. J Natl Cancer Inst. 1993;85(15):1220-1224. [pmid: 8331682].
48 Sturmer T, Glynn RJ, Lee IM, et al. Aspirin use and colorectal cancer: post-trial follow-up data from the Physicians' Health Study. Ann Intern Med. 1998;128(9):713-720. [pmid: 9556464].
49 Giovannucci E, Egan KM, Hunter DJ, et al. Aspirin and the risk of colorectal cancer in women. N Engl J Med. 1995;333(10):609-614. [pmid: 7637720].
50 Schreinemachers DM, Everson RB. Aspirin use and lung, colon, and breast cancer incidence in a prospective study. epi. 1994;5(2):138-146.
51 Sorensen HT, Friis S, Norgard B, et al. Risk of cancer in a large cohort of nonaspirin NSAID users: a population-based study. Br J Cancer. 2003;88(11):1687-1692. [pmid: 12771981].
52 Friis S, Sorensen HT, McLaughlin JK, et al. A population-based cohort study of the risk of colorectal and other cancers among users of low-dose aspirin. Br J Cancer. 2003;88(5):684-688. [pmid: 12618874].
53 Paganini-Hill A. Aspirin and colorectal cancer: the Leisure World cohort revisited. Prev Med. 1995;24(2):113-115. [pmid: 7597009].
54 La Vecchia C, Negri E, Franceschi S, et al. Aspirin and colorectal cancer. Br J Cancer. 1997;76(5):675-677. [pmid: 9303370].
55 Muscat JE, Stellman SD, Wynder EL. Nonsteroidal antiinflammatory drugs and colorectal cancer. Cancer. 1994;74(7):1847-1854. [pmid: 8082089].
56 Suh O, Mettlin C, Petrelli NJ. Aspirin use, cancer, and polyps of the large bowel. Cancer. 1993;72(4):1171-1177. [pmid: 8339210].
57 Kune GA, Kune S, Watson LF. Colorectal cancer risk, chronic illnesses, operations, and medications: case control results from the Melbourne Colorectal Cancer Study. Cancer Res. 1988;48(15):4399-4404. [pmid: 3390835].
58 Shaheen NJ, Silverman LM, Keku T, et al. Association between hemochromatosis (HFE) gene mutation carrier status and the risk of colon cancer. J Natl Cancer Inst. 2003;95(2):154-159. [pmid: 12529348].
59 Juarranz M, Calle-Puron ME, Gonzalez-Navarro A, et al. Physical exercise, use of Plantago ovata and aspirin, and reduced risk of colon cancer. Eur J Cancer Prev. 2002;11(5):465-472. [pmid: 12394244].
60 Coogan PF, Rosenberg L, Louik C, et al. NSAIDs and risk of colorectal cancer according to presence or absence of family history of the disease. Cancer Causes Control. 2000;11(3):249-255. [pmid: 10782659].
61 Collet JP, Sharpe C, Belzile E, et al. Colorectal cancer prevention by non-steroidal anti-inflammatory drugs: effects of dosage and timing. Br J Cancer. 1999;81(1):62-68. [pmid: 10487613].
62 Reeves MJ, Newcomb PA, Trentham-Dietz A, et al. Nonsteroidal anti-inflammatory drug use and protection against colorectal cancer in women. Cancer Epidemiol Biomarkers Prev. 1996;5(12):955-960. [pmid: 8959316].
63 Peleg II, Lubin MF, Cotsonis GA, et al. Long-term use of nonsteroidal antiinflammatory drugs and other chemopreventors and risk of subsequent colorectal neoplasia. Dig Dis Sci. 1996;41(7):1319-1326. [pmid: 8689906].
64 Slattery ML, Samowitz W, Hoffman M, et al. Aspirin, NSAIDs, and colorectal cancer: Possible involvement in an insulin-related pathway. Cancer Epidemiol Biomarkers Prev. 2004;13(4):538-545. [pmid: 15066917].
65 Baron JA, Cole BF, Sandler RS, et al. A randomized trial of aspirin to prevent colorectal adenomas. N Engl J Med. 2003;348(10):891-899. [pmid: 12621133].
66 Benamouzig R, Deyra J, Martin A, et al. Daily soluble aspirin and prevention of colorectal adenoma recurrence: one-year results of the APACC trial. Gastroenterology. 2003;125(2):328-336. [pmid: 12891533].
67 Ladenheim J, Garcia G, Titzer D, et al. Effect of sulindac on sporadic colonic polyps. Gastroenterology. 1995;108(4):1083-1087. [pmid: 7698575].
68 Baron JA, Cole BF, Sandler RS, et al. A randomized trial of aspirin to prevent colorectal adenomas. N Engl J Med. 2003;348(10):891-899. [pmid: 12621133].
69 Benamouzig R, Deyra J, Martin A, et al. Daily soluble aspirin and prevention of colorectal adenoma recurrence: one-year results of the APACC trial. Gastroenterology. 2003;125(2):328-336. [pmid: 12891533].
70 Greenberg ER, Baron JA, Freeman DH Jr. et al. Reduced risk of large-bowel adenomas among aspirin users. The Polyp Prevention Study Group. J Natl Cancer Inst. 1993;85(11):912-916. [pmid: 8492320].
71 Tangrea JA, Albert PS, Lanza E, et al. Non-steroidal anti-inflammatory drug use is associated with reduction in recurrence of advanced and non-advanced colorectal adenomas (United States). Cancer Causes Control. 2003;14(5):403-411. [pmid: 12946034].
72 Logan RF, Little J, Hawtin PG, et al. Effect of aspirin and non-steroidal anti-inflammatory drugs on colorectal adenomas: case-control study of subjects participating in the Nottingham faecal occult blood screening programme. BMJ. 1993;307(6899):285-289. [pmid: 8374373].
73 Hauret KG, Bostick RM, Matthews CE, et al. Physical activity and reduced risk of incident sporadic colorectal adenomas: observational support for mechanisms involving energy balance and inflammation modulation. Am J Epidemiol. 2004;159(10):983-992. [pmid: 15128611].
74 Lieberman DA, Prindiville S, Weiss DG, et al. Risk factors for advanced colonic neoplasia and hyperplastic polyps in asymptomatic individuals. JAMA. 2003;290(22):2959-2967. [pmid: 14665657].
75 Martin C, Connelly A, Keku TO, et al. Nonsteroidal anti-inflammatory drugs, apoptosis, and colorectal adenomas. Gastroenterology. 2002;123(6):1770-1777. [pmid: 12454832].
76 Breuer-Katschinski B, Nemes K, Rump B, et al. Long-term use of nonsteroidal antiinflammatory drugs and the risk of colorectal adenomas. The Colorectal Adenoma Study Group. Digestion. 2000;61(2):129-134. [pmid: 10705177].
77 Kahn HS, Tatham LM, Thun MJ, et al. Risk factors for self-reported colon polyps. J Gen Intern Med. 1998;13(5):303-310. [pmid: 9613885].
78 Sandler RS, Galanko JC, Murray SC, et al. Aspirin and nonsteroidal anti-inflammatory agents and risk for colorectal adenomas. Gastroenterology. 1998;114(3):441-447. [pmid: 9496933].
79 Morimoto LM, Newcomb PA, Ulrich CM, et al. Risk factors for hyperplastic and adenomatous polyps: evidence for malignant potential?. Cancer Epidemiol Biomarkers Prev. 2002;11(10 Pt 1):1012-1018. [pmid: 12376501].
80 Gibbs WJ, Fugate SE, Vesta KS. Optimal antithrombotic management of anticoagulated patients with a history of myocardial infarction. [Review] [16 refs]. Cardiol Rev. 2004;12(6):327-333. [pmid: 15476572].
81 Hart RG, Halperin JL, McBride R, et al. Aspirin for the primary prevention of stroke and other major vascular events: meta-analysis and hypotheses. Arch Neurol. 2000;57(3):326-332. [pmid: 10714657].
82 He J, Whelton PK, Vu B, et al. Aspirin and risk of hemorrhagic stroke: a meta-analysis of randomized controlled trials. JAMA. 1998;280(22):1930-1935. [pmid: 9851479].
83 Weisman SM, Graham DY. Evaluation of the benefits and risks of low-dose aspirin in the secondary prevention of cardiovascular and cerebrovascular events. Arch Intern Med. 2002;162(19):2197-2202. [pmid: 12390062].
84 Serebruany VL, Malinin AI, Eisert RM, et al. Risk of bleeding complications with antiplatelet agents: meta-analysis of 338,191 patients enrolled in 50 randomized controlled trials. Am J Hematol. 2004;75(1):40-47. [pmid: 14695631].
85 Lip GY, Felmeden DC. Antiplatelet agents and anticoagulants for hypertension. [Review][117 refs]. Cochrane Database Syst Rev 2004;(3):CD003186.
86 Derry S, Loke YK. Risk of gastrointestinal haemorrhage with long term use of aspirin: meta-analysis. BMJ. 2000;321(7270):1183-1187. [pmid: 11073508].
87 Garcia Rodriguez LA, Hernandez-Diaz S, de Abajo FJ. Association between aspirin and upper gastrointestinal complications: systematic review of epidemiologic studies. Br J Clin Pharmacol. 2001;52(5):563-571. [pmid: 11736865].
88 Tramer MR, Moore RA, Reynolds DJ, et al. Quantitative estimation of rare adverse events which follow a biological progression: a new model applied to chronic NSAID use. Pain. 2000;85(12):169-182. [pmid: 10692616].
89 Roderick PJ, Wilkes HC, Meade TW. The gastrointestinal toxicity of aspirin: an overview of randomised controlled trials. Br J Clin Pharmacol. 1993;35(3):219-226. [pmid: 8471398].
90 van Es RF, Jonker JJ, Verheugt FW, et al. Aspirin and coumadin after acute coronary syndromes (the ASPECT-2 study): a randomised controlled trial. Lancet. 2002;360(9327):109-113. [pmid: 12126819].
91 Main C, Palmer S, Griffin S, et al. Clopidogrel used in combination with aspirin compared with aspirin alone in the treatment of non-ST-segment-elevation acute coronary syndromes: a systematic review and economic evaluation. [Review] [477 refs]. Health Technol Assess. 2001;8(40):iii-iiv.
92 Wang WH, Huang JQ, Zheng GF, et al. Non-steroidal anti-inflammatory drug use and the risk of gastric cancer: a systematic review and meta-analysis. [Review] [74 refs]. J Natl Cancer Inst. 2003;95(23):1784-1791. [pmid: 14652240].
93 Juni P, Nartey L, Reichenbach S, et al. Risk of cardiovascular events and rofecoxib: cumulative meta-analysis. Lancet. 2004;364(9450):2021-2029. [pmid: 15582059].
94 Ofman JJ, MacLean CH, Straus WL, et al. A metaanalysis of severe upper gastrointestinal complications of nonsteroidal antiinflammatory drugs. J Rheumatol. 2002;29(4):804-812. [pmid: 11950025].
95 Ofman JJ, MacLean CH, Straus WL, et al. Meta-analysis of dyspepsia and nonsteroidal antiinflammatory drugs. Arthritis Rheum. 2003;49(4):508-518. [pmid: 12910557].
96 Rostom, A., Dube, C., Jolicoeur, E., Boucher, M., and Joyce, J. Gastroduodenal ulcers associated with the use of non-steroidal anti-inflammatory drugs: a systematic review of preventative pharmacological interventions. Ottawa: CCOHTA, 2004. Technology Report Issue 38.
97 Hooper L, Brown TJ, Elliott R, et al. The effectiveness of five strategies for the prevention of gastrointestinal toxicity induced by non-steroidal anti-inflammatory drugs: systematic review. BMJ. 2004;329(7472):948. [pmid: 15475342].
98 Huang JQ, Sridhar S, Hunt RH. Role of Helicobacter pylori infection and non-steroidal anti-inflammatory drugs in peptic-ulcer disease: a meta-analysis. Lancet. 2002;359(9300):14-22. [pmid: 11809181].
99 Silverstein FE, Graham DY, Senior JR, et al. Misoprostol reduces serious gastrointestinal complications in patients with rheumatoid arthritis receiving nonsteroidal anti-inflammatory drugs. A randomized, double-blind, placebo-controlled trial. Ann Intern Med. 1995;123(4):241-249. [pmid: 7611589].
100 Silverstein FE, Faich G, Goldstein JL, et al. Gastrointestinal toxicity with celecoxib vs nonsteroidal anti-inflammatory drugs for osteoarthritis and rheumatoid arthritis: the CLASS study: A randomized controlled trial. Celecoxib Long-term Arthritis Safety Study. JAMA. 2000;284(10):1247-1255. [pmid: 10979111].
101 Bombardier C, Laine L, Reicin A et al. Comparison of upper gastrointestinal toxicity of rofecoxib and naproxen in patients with rheumatoid arthritis. VIGOR Study Group. N Engl J Med 2000; 343(21):1520–8, 2.
102 Goldstein JL, Eisen GM, Agrawal N, et al. Reduced incidence of upper gastrointestinal ulcer complications with the COX-2 selective inhibitor, valdecoxib. Aliment Pharmacol Ther. 2004;20(5):527-538. [pmid: 15339324].
103 Suleiman S, Rex DK, Sonnenberg A. Chemoprevention of colorectal cancer by aspirin: a cost-effectiveness analysis. Gastroenterology. 2002;122(1):78-84. [pmid: 11781283].
104 Hur C, Simon LS, Gazelle GS. The cost-effectiveness of aspirin versus cyclooxygenase-2-selective inhibitors for colorectal carcinoma chemoprevention in healthy individuals. Cancer. 2004;101(1):189-197. [pmid: 15222006].
105 Arguedas MR, Heudebert GR, Wilcox CM. Surveillance colonoscopy or chemoprevention with COX-2 inhibitors in average-risk post-polypectomy patients: a decision analysis. Aliment Pharmacol Ther. 2001;15(5):631-638. [pmid: 11328256].
106 Ladabaum U, Scheiman JM, Fendrick AM. Potential effect of cyclooxygenase-2 - Specific inhibitors on the prevention of colorectal cancer: A cost-effectiveness analysis. Am J Med. 2003;114(7):546-554. [pmid: 12753878].
107 Cook NR, Lee IM, Gaziano JM, et al. Low-dose aspirin in the primary prevention of cancer: the Women's Health Study: a randomized controlled trial. JAMA. 2005;294(1):47-55. [pmid: 15998890].
108 Chan AT, Giovannucci EL, Meyerhardt JA, et al. Long-term use of aspirin and nonsteroidal anti-inflammatory drugs and risk of colorectal cancer. JAMA. 2005;294(8):914-923. [pmid: 16118381].
109 Schnitzer TJ, Burmester GR, Mysler E, et al. Comparison of lumiracoxib with naproxen and ibuprofen in the Therapeutic Arthritis Research and Gastrointestinal Event Trial (TARGET), reduction in ulcer complications: randomised controlled trial. Lancet. 2004;364(9435):665-674. [pmid: 15325831].
110 Henry D, Lim LL, Garcia Rodriguez LA, et al. Variability in risk of gastrointestinal complications with individual non-steroidal anti-inflammatory drugs: results of a collaborative meta-analysis. BMJ. 1996;312(7046):1563-1566. [pmid: 8664664].
111 Serebruany VL, Steinhubl SR, Berger PB, et al. Analysis of risk of bleeding complications after different doses of aspirin in 192,036 patients enrolled in 31 randomized controlled trials. Am J Cardiol. 2005;95(10):1218-1222. [pmid: 15877994].
112 Topol EJ. Failing the public health—rofecoxib, Merck, and the FDA. N Engl J Med. 2004;351(17):1707-1709. [pmid: 15470193].
113 Topol EJ. Arthritis medicines and cardiovascular events—“house of coxibs”. JAMA. 2005;293(3):366-368. [pmid: 15623849].
114 Hippisley-Cox J, Coupland C. Risk of myocardial infarction in patients taking cyclo-oxygenase-2 inhibitors or conventional non-steroidal anti-inflammatory drugs: population based nested case-control analysis. BMJ. 2005;330(7504):1366. [pmid: 15947398].
115 Kimmel SE, Berlin JA, Reilly M, et al. The effects of nonselective non-aspirin non-steroidal anti-inflammatory medications on the risk of nonfatal myocardial infarction and their interaction with aspirin. J Am Coll Cardiol. 2004;43(6):985-990. [pmid: 15028354].
116 Mamdani M, Rochon P, Juurlink DN, et al. Effect of selective cyclooxygenase 2 inhibitors and naproxen on short-term risk of acute myocardial infarction in the elderly. Arch Intern Med. 2003;163(4):481-486. [pmid: 12588209].
117 Rahme E, Pilote L, LeLorier J. Association between naproxen use and protection against acute myocardial infarction. Arch Intern Med. 2002;162(10):1111-1115. [pmid: 12020180].
118 Ray WA, Stein CM, Hall K, et al. Non-steroidal anti-inflammatory drugs and risk of serious coronary heart disease: an observational cohort study. Lancet. 2002;359(9301):118-123. [pmid: 11809254].
119 Ray WA, Stein CM, Daugherty JR, et al. COX-2 selective non-steroidal anti-inflammatory drugs and risk of serious coronary heart disease. Lancet. 2002;360(9339):1071-1073. [pmid: 12383990].
120 Garcia Rodriguez LA, Varas-Lorenzo C, Maguire A, et al. Nonsteroidal antiinflammatory drugs and the risk of myocardial infarction in the general population. Circulation. 2004;109(24):3000-3006. [pmid: 15197149].
121 Schlienger RG, Jick H, Meier CR. Use of nonsteroidal anti-inflammatory drugs and the risk of first-time acute myocardial infarction. Br J Clin Pharmacol. 2002;54(3):327-332. [pmid: 12236854].
122 Solomon DH, Glynn RJ, Levin R, et al. Nonsteroidal anti-inflammatory drug use and acute myocardial infarction. Arch Intern Med. 2002;162(10):1099-1104. [pmid: 12020178].
123 Watson DJ, Rhodes T, Cai B, et al. Lower risk of thromboembolic cardiovascular events with naproxen among patients with rheumatoid arthritis. Arch Intern Med. 2002;162(10):1105-1110. [pmid: 12020179].
124 Food and Drug Administration. COX-2 Selective (includes Bextra, Celebrex, and Vioxx) and Non-Selective Non-Steroidal Anti-Inflammatory Drugs (NSAIDs). Available at: http://www.fda.gov/medwatch/SAFETY/2005/safety05.htm#NSAID 2005.