# Discussion

CRC is a frequent cause of morbidity and mortality in the United States. Chemoprevention with ASA or NSAIDs is one possible strategy to reduce the burden associated with this disease. The results of this report suggest that such a strategy may be effective, but also that the possible harms of chemoprevention and its cost effectiveness have to be considered. New data regarding the effectiveness of chemoprevention using COX-2 inhibitors are likely to become available in the upcoming year, and our understanding of the CV harms of these agents and of non-ASA NSAIDs is evolving.

The regular use of ASA appears to be effective in reducing the incidence of CRA with RRR, on the order of 13% to 28% in average-risk individuals. The use of non-ASA NSAIDs appears to be associated with somewhat higher RRRs, on the order of 23% to 46%. Based on a limited number of studies, the RRRs for higher risk individuals are likely higher than for those at average risk. Furthermore, it appears that longer use of ASA/NSAIDs, particularly if that use continued to the year prior to the ascertainment of the study outcome, as well as higher doses, is associated with greater RRRs than shorter-term and lower-dose use.

The findings reported above also hold for CRC incidence. Regular use of ASA was associated with RRRs of 10% to 65% for CRC incidence. The analysis for the case-control studies demonstrated significant heterogeneity, but based on a pooled RRR of 22% in the cohort studies and consideration of the included studies, RRRs in CRC incidence of 15% to 40% represents a more realistic range. The pooled estimates for non-ASA NSAIDs suggest somewhat greater RRRs, on the order of 30% to 40%, and longer duration of use of ASA/NSAIDs and higher doses also appear to offer greater protection. Data from two RCTs, however, demonstrated no clear benefit of ASA on CRC incidence. ^47,^ ^107^

Only two observational studies considered the effect of ASA/NSAIDs on CRC mortality. ^45,^ ^46^ Among the observational studies, CRC mortality was reduced by about 40% with the use of ASA for greater than 15 years in one, ^45^ while the other found nonsignificant trends towards increased standardized mortality ratios for bowel and rectal cancers with ibuprofen. ^46^ Table 5 (Appendix 8) summarizes the main results and lists the effects of various screening strategies detailed in the USPSTF recommendation on CRC screening.

Table 5.1 Regular use of NSAIDs on CRA incidence

Design | Agent | Group | RR
Case Control | ASA | Average risk | RR=0.87; 95% CI:0.77–0.98
| Non-ASA NSAID | Average risk | RR=0.54; 95% CI:0.4–0.74
| ‘any NSAID’ | Average risk | RR=0.57; 95% CI: 0.46–0.71
| | Higher risk (1 study) | RR=0.21; 95% CI: 0.04–0.99
Cohort | ASA | Average risk | RR=0.72; 95% CI: 0.61–0.85
| | Higher risk (1 study) | RR=0.52; 95% CI: 0.31–0.89
| Non-ASA NSAID | n/a | n/a
| ‘any NSAID’ | Average risk | RR=0.77; 95% CI:0.63–0.95
| | Higher risk (1 study) | RR= 0.69; 95% CI: 0.55–0.88
RCTs | ASA | Low dose - higher risk | RR=0.82; 95% CI:0.7–0.95
| Non-ASA NSAID | Higher risk - CRA regression | 1.65 (ns)

Nurses's Health Study - Cohort (2005) included > 14 tablets / week RR=0.49 (CI, 0.36 to 0.65)

Table 5.2 Regular use of NSAIDs on CRC incidence

Design | Agent | Group | RR
Case Control | ASA | Average risk | Hetero RR=0.3 to 0.9
| Non-ASA NSAID | Average risk | RR=0.70; 95%: 0.63–0.78
| ‘any NSAID’ | Average risk | Hetero RR=0.13–0.80
Cohort | ASA | Average risk | RR=0.78; 95% CI: 0.63–0.97
| Non-ASA NSAID | Average risk (1 study) | RR= 0.61; 95% CI:0.48–0.77
| ‘any NSAID’ | n/a | n/a
RCTs | ASA | Average risk (1 study) | RR=1.15; 95% CI:0.80, 1.65
| Non-ASA NSAID | n/a | n/a

Women's Health Study - July 2005 - RCT - no effect of 100mg ASA ever other day

Nurses Healthy Study AUG 2005 - Cohort -14 aspirin/week > 10 years RR= 0.47 (95% CI:0.31–0.71) - effect dose dependant

Table 5.3 Regular use of NSAIDs on CRC mortality

Design | Agent | Group | RR
Cohort | ASA (1 study-Thun) | average risk men | RR=0.58; 95% CI:0.36–0.93
| | average risk women | RR=0.61; 95% CI:0.38–0.97
| Non-ASA NSAID (1 study-Lipworth) | Average risk - bowel ca | SMR=1.05; 95% CI: 0.9–1.2
| | Rectal ca | SMR=1.26; 95% CI:1.0–1.5

Women's Health Study - July 2005 - RCT - no effect of 100mg ASA ever other day

Table 5.4 USPSTF—Screening Average risk on CRC mortality

Method | RR | RRR | ARR (per 1000)
FOBT | 67%–75% | 15%–33% | 0.8–4.6
FOBT+Sigmoidoscopy | 56% | 44% | 0.27
Sigmoidoscopy* | 41% | 59%
Colonoscopy* | 57% | 43%
Sigmoidoscopy followed by colonoscopy | 20% (incidence) | 80% (incidence)

* limited data

## Limitations

The body of evidence included in this systematic review was quite consistent in suggesting reductions in CRA and CRC incidence with ASA/NSAIDs. However, the included studies demonstrated important variability in how they were conducted, a circumstance which necessitated careful assessment and grouping of the studies in an effort to minimize this variability. Nonetheless, some variability could not be completely explained. These types of study differences centered around how cases, controls and outcomes were ascertained (i.e., directly, or from hospital records or databases). But perhaps more problematic were differences among the studies in how NSAID exposure was ascertained and measured; for example, through prescriptions databases or from mailed self-administered questionnaires. Measurement and exposure ascertainment introduces a degree of uncertainty in the interpretation of the dose-response relationship and duration-of-use analyses. These concerns also affected the base analyses of regular use, but were not as problematic. It is possible that the effect of ASA/NSAIDs varies in different populations. These study population differences may also have contributed to the observed heterogeneity in some analyses. We tried to minimize the variability relating to duration and dose effects by defining a priori subgroups and using qualitative descriptions of studies when necessary.

The effect of ASA/NSAIDs on CRC mortality represents another area of uncertainty, due to the limited number of studies and the discordance between the included cohort studies. Furthermore, the observational studies suggest a reduction in CRC incidence with chemoprevention, but the widely cited PHS and the recently published Women's Health Study (WHS) found no benefit of ASA on CRC incidence. The PHS and the WHS were well conducted RCTs that share many similarities. They were conducted in male physicians and female health care workers, respectively. Both used a relatively low dose of ASA (325mg every second day and 100mg every second day, respectively), and both used self reporting of outcomes in mailed questionnaires, as well as mailed medication packs. Both studies followed patients for a long period of time (14 and 10 years, respectively), but in the case of the PHS, the RCT portion was the first 5 years and was followed by an observational phase, where patients chose their intervention; the WHS continued the RCT design for the entire study. The PHS study could be criticized for its observational phase which could have introduced several forms of bias, including contamination by intervention. Additionally, participants in the study had a lower rate of CRC than matched members of the U.S. population (SMR =0.82; 95% CI, 0.75 to 0.90). The strength of their RCT design adds weight to their negative findings regarding the benefit of ASA on CRC incidence. However, participants in both studies were relatively young males (mean age 53.2 years, and 54.6 years, respectively) who used a relatively small amount of ASA (every second day). Participants were also not necessarily CRA free at study onset, and outcomes were collected through mailed questionnaires. It is difficult to entirely reconcile the discrepancy between the negative RCT data, and the overwhelmingly positive observational data, other than to say that low-dose ASA every second day is not effective at reducing CRC incidence, but that higher doses used for longer periods may be effective. The recently published follow-up to the Nurse's Health Study, a prospective cohort study including 82, 911 women, adds support to this conclusion. ^108^ This study demonstrated a statistically significant RRR in CRC incidence with ASA. The study also demonstrated an important dose and duration effect, with the maximal benefit seen when more than 14 standard ASA tablets were used for more than 10 years. The data regarding CRC-related mortality is also mixed. One cohort study was positive, while another was negative. The recently published WHS also showed no effect of ASA on colorectal cancer mortality.

The current review identified no COX-2 chemoprevention studies in average-risk individuals. The results of the Adenomatous Polyp Prevention on Vioxx (APPROVe) trial, and two celecoxib spontaneous adenomatous polyposis (SAP) prevention trials (APC and preSAP) are not yet available. Furthermore, two of these trials, and an Alzheimer's prevention trial, have caused considerable upheaval in the current state of understanding of the CV safety of COX-2 inhibitors and non-ASA-NSAIDs. ^7,^ ^8^

Subjects at “high risk” of CRC, such as those with previous CRC or those with hereditary CRC syndromes, represent a distinct group that was not assessed in this review. It is likely that the balance of efficacy and harms for these individuals is different than that presented here for average- and higher-risk individuals.

## Harms

The use of ASA, non-ASA NSAIDs, and COX-2 inhibitors are each associated with important harms. ASA and non-ASA NSAIDs are associated with an increased risk of ulcers and clinically important ulcer complications such as hemorrhage, perforation or pyloric obstruction. The annualized incidence of these events for non-ASA NSAIDs, as a group, is approximately 1.5% to 2.0% in average-risk individuals with arthritis. ^100,^ ^101^ As a “class,” COX-2 inhibitors are associated with fewer endoscopic ulcers and clinically important ulcer complications when compared with non-ASA NSAIDs overall, with pooled RRRs of about 50% for important ulcer complications. As a class, COX-2 inhibitors are associated with fewer GI symptoms than NSAIDs. However, the use of a COX-2 inhibitor among ASA users was assessed in a subgroup of patients in the CLASS (celecoxib), ^100^ Target (lumiracoxib) ^109^ and the Goldstein valdecoxib ^102^ trials. In this setting, the frequency of clinically important ulcer complications were not different between COX-2 inhibitors and non-ASA NSAID users. ASA added to celecoxib appears to result in a four-fold increase in ulcer complications over celecoxib alone, ^96,^ ^100^ and the combination of valdecoxib and ASA results in a nine-fold increase in ulcer complications over valdecoxib alone. ^102^

The use of ASA is associated with an increased incidence of important ulcer complications, with RRs of 1.5 to 3.0 reported in the current evidence report. Furthermore, Henry et al. found that ASA appears to show rates of GI toxicity between those of diclofenac and sulindac. ^110^ The absolute risk of GI bleeding with less than 100mg ASA/day was 0.97% per year and 2.69% per year for greater than 200 mg/day. ^111^ The CV outcomes associated with the use of ASA depend on the underlying CV risk of the population under investigation. In low-to-average risk individuals (i.e., primary prevention), ASA significantly reduces the incidence of total CV events (RR=0.72; 95% CI:0.60–0.87), but has no effect on coronary heart disease mortality, fatal and nonfatal stroke events, or all-cause mortality. In low-to-moderate risk individuals, the use of ASA would prevent three to eight fatal or non-fatal coronary heart disease events, but would not prevent an ischemic stroke event, and would cause one hemorrhage stroke and one major GI hemorrhage (based on 1,000 treated patients). ^2^ In high-risk CV patients in a secondary prevention setting, the use of ASA significantly reduces all-cause mortality and CV mortality, despite the increased incidence of major GI hemorrhage. Weisman et al. suggested that 67 patients would need to be treated to prevent one death, with the cost of one non-fatal GI bleed. They further suggest that two strokes could be prevented for every GI bleed caused. ^83,^ ^86^ In the setting of CRC chemoprevention with ASA, depending on what age the intervention is started, it is possible that most patients would be at low-to-moderate CV risk, and may be exposed more to the harms of ASA rather than to its benefits.

Data on the effectiveness of COX-2 inhibitors for the chemoprevention of CRA and CRC were unavailable to us, and during the conduct of this review rofecoxib was withdrawn from the market based on the results of the polyp prevention APPROVe study, ^112^ which demonstrate a 16/1,000 excess risk of CV events, confirming the suspicions brought out by the VIGOR trial. ^101^ Subsequently, celecoxib was also found to have a 13–21/1,000 excess risk of CV events in another polyp prevention study (APC). ^113^ Valdecoxib was also withdrawn on the basis of excess CV risk in two short term cardiac surgery pain studies (CABG 1 & 2), and due to rare dermatological toxicity. ^7,^ ^8^ The data are, however, far from clear at present. Celecoxib did not show the same CV risk in a second polyp trial and in an Alzheimer's prevention trial, while based on the Alzheimer's trial it was suggested that naproxen may carry an increased CV risk. ^7,^ ^8^ Also in the Target study, Lumiracoxib appears not to be associated with increased CV risk. ^109^

Our report only identified one systematic review of CV harms of non-ASA NSAIDs. ^93^ This review suggested a small CV protective effect, although the included studies were heterogeneous. Clinical trial data of the quality available for the COX-2 inhibitors are not available for the non-ASA NSAIDs, and is likely forthcoming from analyses of the non-ASA NSAID arms of these COX-2 inh trials. However, we assessed the CV harms of non-ASA NSAIDs in the studies identified in the systematic review by Juni ^93^ and in a recent publication by Hippisley-Cox. ^114^ – ^123^ Overall, non-ASA NSAIDs, and particularly non-naproxen NSAIDs, appear to offer no cardioprotective effects, and in some studies there appears to be an increased risk of CV harms with non-naproxen NSAIDs. ^114,^ ^118,^ ^123^

The evidence relating to the CV harms of COX-2 inhibitors and NSAIDs is in a state of rapid flux. In addition to the sources used in the systematic review we have included other sources of data in the Discussion. After the FDA advisory panel meeting of Feb 16, 2005, Health Canada also convened an advisory panel of experts on June 9th 2005 in Ottawa, Canada to provide advice to the Department on the safety and efficacy of COX-2. Dr. Alaa Rostom, the clinical lead author of the present evidence report, was a member of this panel. No information obtained as part of the evidence report was released to the panel.

During the public forum portion of the panel meeting a meta-analysis was presented using an extensive set of RCT data provided by manufacturers. It is difficult to determine the completeness of the data set, but it appeared that the manufacturers provided the required CV data from their clinical trials. The results suggested that as a group, COX-2 inhibitors are associated with an increased risk of CV outcomes when compared with placebo or naproxen, but not when compared with non-naproxen NSAIDs. These data also suggest that the increased risk of CV harms with COX-2 inhibitors is shared by the non-naproxen NSAIDs. Furthermore on June 15^th^ 2005, the FDA requested that all sponsors of marketed prescription NSAIDs, including COX-2 inhibitors, revise their labeling to include a boxed warning highlighting the potential for increased risk of CV events, in addition to the well-described GI toxicity associated with these agents. ^124^

## Cost-effectiveness

In average-risk populations, and in the context of regular endoscopic screening for CRC, NSAID chemoprevention is at present not cost-effective because of the relatively large costs associated with its adverse effects, as well as its relative inefficacy compared with colonoscopy. To be cost-effective, daily ASA use would have to decrease the CV mortality by 0.1% or more, and it would have to decrease CRC mortality by at least 30%. Additionally, chemoprevention with COX-2 inhibitors, independently of the newly recognized cardiotoxicity, is expensive, and its use as an adjunct to colonoscopy can only be economically acceptable (i.e., ICER less than $100,000/LY saved) if it can prevent CRC mortality by at least 60%, and the cost be reduced by at least 75%.

In higher-risk groups, the use of COX-2 inhibitors for chemoprevention of CRC is both less effective and considerably more costly than screening protocols, which are in themselves cost effective by all criteria; the use of COX-2 inhibitors as an adjunct to screening can only be economically acceptable if their current cost is considerably reduced and if their efficacy as chemopreventive agents is of at least 50%. These results do not account for any potential CV harms of COX-2 use.

## Conclusions

ASA and non-ASA NSAIDs appear to be effective at reducing the incidence of CRAs and CRC. However, the data on CRC incidence is inconsistent, with observational studies tending to be positive, and two large RCTs showing no benefit for low-dose ASA every second day on CRC incidence. The effect of ASA/NSAIDs on CRC mortality is also mixed, with one positive and one negative cohort study, and the negative findings of the WHS. There are well-defined GI risks associated with ASA and NSAIDs when used daily for months. There are no quantitative data on GI or CV risk of chronic multiyear use of daily NSAIDs. We found no information regarding the effectiveness of COX-2 inhibitors on these outcomes in average-risk individuals. Available data on COX-2 inhibitors suggest that absolute risk increase of over 1% for CV events can be anticipated from only 2 to 3 years use, and higher risks may accrue over longer periods. Further, the results of the economic evaluations consistently reveal that chemoprevention is not cost effective. In the case of ASA, the costs of complications are significant; in the case of COX-2 inhibitors, independently of the recently reported CV toxicity, the drug costs are great. Lastly, in addition to their emerging CV toxicity, non-ASA NSAIDs, are associated with significant GI harms. Arguments can be made for the use of ASA chemoprevention, particularly in populations that may benefit from its CVS harms preventive effect. However, since observational studies suggest that higher doses and prolonged use improve chemopreventative efficacy, more information is required to clarify the optimal dose, starting age, and duration of use of ASA, as well as clarification of its effect on CRC incidence and mortality, particularly given the evidence that in patients at average CV risk, all-cause mortality is not reduced with the use of ASA.

## Future research

COX-2 inhibitors appeared poised due to their GI safety to be the ideal candidates for CRC chemoprevention. However, the recent data regarding the CV harms of COX-2 inhibitors, and possibly of non-naproxen NSAIDs, have put this expectation into question. Nonetheless, data from the Vioxx and Celebrex polyp prevention trials need to be made available so as to at least test the hypothesis that COX-2 inhibition is clinically effective at reducing polyp occurrence.

Furthermore, because of the discrepancy between the RCT data (PHS and WHS), and the observational study data, it would seem prudent to assess the role of standard daily doses of ASA by means of an RCT designed for the sole purpose of assessing its effect on polyp and CRC incidence. Other questions also need to be answered; for example, “What is the effective dose of ASA?” and “At what age should chemoprevention should start?”.

There is strikingly little data on the long term (>2–3 years) harms of NSAIDs and COX-2 inhibitors. Studies of pharmacologic therapies in general, and preventive strategies in particular, that use these agents should incorporate outcomes such as overall mortality, hospitalization, and serious adverse effects. It is known that GI bleeding risk with NSAIDs increases with advancing age and underlying CV disease; that is, the risk is heightened in the very same population in which chemoprevention may be utilized. Further study should be undertaken on the balance of harms and benefits in this particular population, with particular emphasis on the cumulative harms over the time period over which chemoprevention is likely to be used.

Reliable estimates of compliance rates with chemoprevention need to be determined and compared with those of current and potential screening-based preventive methods.