# Methods

The current University of Ottawa EPC's evidence report on the use of aspirin and NSAIDs to prevent CRC is based on a systematic review of the scientific-medical literature which identified and synthesized the results from studies addressing key questions developed in consultation with the USPSTF. The analytical framework presented in Figure 1 was used to guide the development of the literature search in order to address the key questions related to the value and harms related to the use of ASA and NSAIDs for the prevention of CRA, CRC, and mortality reduction. A more comprehensive description of the methods is provided in Appendix 4.

Figure 1. Analytic framework: aspirin/NSAID to prevent colorectal cancer

## Key questions

The purpose of this evidence report was to synthesize information from relevant studies to address the following basic questions:

- Does aspirin/NSAID use in healthy adults (> 18 years of age) decrease CRC mortality and/or all-cause mortality? (Question 1A)
- What is the magnitude of decreased CRC incidence due to aspirin/NSAID chemoprevention in healthy adults? (Question 1B)
  a What is the impact (benefits and harms) of different doses of aspirin and of the different classes of NSAIDs?
  b What is the impact (benefits and harms) for aspirin/NSAID therapy in persons at different levels of CRC risk?
- What is the magnitude of decreased CRA incidence due to aspirin/NSAID chemoprevention in healthy adults? (Question 2)
- What is the magnitude of decreased CRA on CRC in healthy adults? (Question 3)
- What is the magnitude of harms of aspirin/NSAID use in healthy adults (i.e. increased major GI bleeding, hemorrhagic stroke or nephropathy)? (Question 4)

## Literature search and strategy

The strategy was developed in Medline and modified for the other databases. For questions 1 and 2, three main concepts were included: NSAIDs or chemoprevention, CRC or intestinal polyps, and relevant study designs. Study designs sought were randomized controlled trials (RCTs), case-control and cohort studies. A comprehensive retrieval strategy for NSAIDs was derived from indexing both Medline and Embase, using reviewer-nominated terms, and examining previous reviews. ^10^ – ^14^

Terms were derived from the National Cancer Institute (NCI) Cancer topic searches for “Colorectal Cancer” and “Adenomatous polyps.” The search was limited to the English language and non-human studies were excluded (Appendix 1). Databases searched were Medline 1966-November week 3, 2004, Embase 1980-week 47 2004 (publication years 2003-2005 only), CENTRAL, and The Cochrane Library Issue 4, 2004. Pubmed Cancer subset was searched for non-Medline material. This search used the NCI search strategy for CRC with free text terms for NSAIDs and COX-2 inhibitors, and was conducted on December 1, 2004.

Additional material for the economic analysis question was sought in Medline (1966 to November Week 3 2004), HealthStar (1987 to November 2004), Embase (1980 to 2004 Week 50), Cochrane Library 4th Quarter 2004, NHS EED, and HTA. The TRIP (www.tripdatabase.com) database was searched December 14, 2004.

A search strategy to detect recent systematic reviews of NSAIDs that appeared to address harm was developed and run in Medline (2003 to November Week 3 2004). Cochrane Database of Systematic Reviews (CDSR) and DARE (Cochrane Library, 3rd Quarter 2004) were searched without date restrictions for all systematic reviews related to NSAIDS.

We implemented a weekly monitoring strategy to detect emerging information on CV harms associated with COX-2 inhibitors. We also monitored the FDA news digest and Health Canada's Health Product Information mailing list for announcements related to COX-2 inhibitors and CV harms (monitoring dates Jan 14, 2005– May 26, 2005).

## Study selection methods

### 1) Effect of NSAIDs on the risk of CRC and/or CRAs

Screening of articles for inclusion was conducted for each screening level by two members of the review team (Appendix 2). An initial screening level to identify potentially relevant articles was followed by a relevance assessment to identify articles meeting inclusion criteria. Conflicts were resolved by consensus.

A third level of screening was included (for questions 1 and 2) to discriminate the different study designs (Appendix 4). Data abstraction (Appendix 2) was performed by one reviewer and was checked by a second reviewer.

#### Inclusion/exclusion criteria (efficacy)

[underlined: Design]: RCTs, controlled clinical trials, and observational studies (cohorts and case-control) were considered for inclusion if they fulfilled the population, intervention, and outcome criteria detailed below.

[underlined: Population]: Participants at “average-risk” for CRC (i.e., no known risk factors for CRA or CRC other than age); a personal or family history of CRA; or, a family history of sporadic CRC. Familial adenomatous polyposis (FAP) or hereditary non-polyposis colon cancer syndromes (Lynch I or II) were excluded since these syndromes account for a small percentage of CRC. Secondary prevention studies of patients with a personal history of CRC were also excluded.

[underlined: Interventions]: Included studies assessed the efficacy or effectiveness of ASA, and non-ASA NSAIDs, including COX-2 inhibitors.

[underlined: Outcomes]: The incidence of CRA and/or CRC; reductions in CRC-related mortality or overall mortality.

### 2) Harms

The GI, CV, and renal harms associated with the use of ASA, non-ASA NSAIDs, and COX-2 inhibitors were sought through identification of systematic reviews due to the vast amount of reviews already done on these topics (see Appendix 5 for more details).

### 3) Cost-effectiveness

A specific search was conducted to identify cost-effectiveness analyses of chemoprevention with ASA or non-ASA NSAIDs for the prevention of the above listed endpoints.

We used predefined criteria from the USPSTF to assess the internal validity of included systematic reviews, trials and observational studies, which we rated as “good”, “fair”, or “poor” (Appendix 3). A description of the quantitative analysis can be found in Appendix 4.

Figures and Tables are depicted in Appendix 8.