# Introduction

This systematic review examines the evidence for the effectiveness of aspirin (ASA) and non-aspirin nonsteroidal anti-inflammatory drugs (non-ASA NSAIDs), including cyclooxygenase-2 (COX-2) inhibitors, for the prevention of colorectal adenomas (CRAs), colorectal cancer (CRC), and mortality in asymptomatic individuals. The review also examines the harms associated with the long-term use of these agents, as well as their cost-effectiveness in the setting of chemoprevention.

## Background

Cancer accounts for 23% of all deaths in the U.S. It is the second leading cause of death after heart disease overall, and the leading cause of death in those under the age of 65. CRC is the third most common type of cancer in both men and women, and is also the second leading cause of cancer-related deaths. In 2004, it is estimated that there were 146,940 new cases of CRC, and that 56,730 died of the disease (11% and 10% of all cancers, respectively). The incidence of CRC declined beginning in the early 1980s, but has leveled out since the mid-90's; whereas mortality from CRC has continued to decline. ^1^

Age is a major risk factor for CRC, with approximately 90% of cases occurring after 50 years of age. ^1^ Other risk factors for CRC include: a family history of sporadic CRC or colonic polyps; hereditary polyposis and non-polyposis colon cancer syndromes; inflammatory bowel disease; and, other factors such as cholecystectomy, diabetes mellitus, alcoholism, and smoking. Hereditary CRC syndromes account for less than 5% of CRC cases.

## Strategies for the prevention of CRC and CRC-related mortality

Two main strategies exist for the prevention of CRC. First, and currently promoted by most medical societies, is screening-based prevention. This strategy relies on the early detection of premalignant polyps and/or early stage CRC. Since it is widely accepted that adenomatous polyps are the precursors of the vast majority of CRC, the early detection and removal of these precursor lesions is presumed to reduce the incidence of CRC, and its related mortality. Even cancers detected by screening are potentially early stage and curable.

CRC fulfills many of the characteristics of a disorder that would benefit from screening at-risk individuals. The disorder has a long and typically clinically silent premalignant and early malignant stage, which can be detected by relatively safe and commonly performed tests. The treatment of the premalignant (polyp) stage and the early malignant stage is highly effective. Surgical treatment of early stage CRC is typically curative without the need for additional therapy. This subject has recently been reviewed by the USPSTF. ^2^ Several screening methods are available and have been shown to be effective. However, despite the evidence of effectiveness, adoption of widespread routine screening of eligible individuals by any method continues to be low in the U.S. ^3^ – ^6^

An alternate or possibly complementary strategy to screening is a preventive strategy. This can include a variety of lifestyle and dietary changes or, as the focus of this report, chemoprevention. Several basic science, population-based, and experimental studies have suggested a protective effect of aspirin (ASA) and non-ASA non-steroidal anti-inflammatory drugs (non-ASA NSAIDs), including COX-2 inhibitors (COX-2 inhibitors), on CRA and CRC. However, these agents are not without harms. Significant gastrointestinal (GI) hemorrhage can occur with all of these agents, though to a lesser extent with the COX-2 inhibitors. Furthermore, these agents have varying cardiovascular and renal toxicities, and recent interest has focused on a potentially prothrombotic effect of selective COX-2 inhibitors. In fact, during the conduct of the present review, two COX-2 inhibitors (rofecoxib, valdecoxib) were withdrawn from the market because of concerns regarding their cardiovascular toxicity, leaving only celecoxib and meloxicam (the least COX-2 selective agents) remaining, and uncertainty regarding the future of others, such as lumiracoxib and etoricoxib. These developments have thrown our understanding of the safety of COX-2 inhibitors and even non-ASA NSAIDs into a state of uncertainty. This is particularly true because it is apparent that although there is a great deal of clinical trial data regarding the safety of these agents, it is available only to a select few, such as those with contacts with manufacturers or regulatory agencies. These developments also have an impact on this review, not only because of the proprietary nature of some of the harms data derived from recent clinical trials, but also because three of the clinical trials were COX-2 polyp prevention trials (Adenomatous Polyp Prevention on Vioxx [APPROVe] trial, and two celecoxib spontaneous adenomatous polyposis [SAP] prevention trials [APC, and preSAP]) ^7,^ ^8^ The results of the efficacy portion of these trials are currently unavailable.

These potential harms also have to be considered in light of the potentially long period of exposure to these agents when used for CRC prevention, and specifically whether the harms with prolonged use of these agents are outweighed by their potential benefits, as judged by more objective clinical outcomes such as overall mortality reductions. Furthermore, reductions in CRC mortality would have to be great enough to compete with the mortality reductions of 21% with simple bi-yearly fecal occult blood testing (FOBT), or the 60% reduction with flexible sigmoidoscopy for lesions within reach of that instrument. Further, there are data to suggest that sigmoidoscopy followed by colonoscopy when polyps are found could decrease CRC incidence by up to 80%. ^9^ The USPSTF strongly recommends screening of men and women over the age of 50 (A recommendation). ^2^

If a preventive strategy with NSAIDs is not as effective as screening, it may still have a role as an adjunct, but the risks and cost-effectiveness would need to be favorable.

The purpose of this report was to systematically review the literature on the effectiveness of ASA, non-ASA-NSAIDs, and COX-2 inhibitors, for the chemoprevention of CRC and CRC-related mortality in average-risk individuals. The review also assessed the harms associated with the use of these agents and their cost effectiveness.