# Acknowledgments

This Evidence Synthesis was funded by the Centers for Disease Control and Prevention (CDC) for the AHRQ and the US Preventive Services Task Force (USPSTF), and the investigators acknowledge the contributions of Mary White, ScD, Chief Epidemiology and Applied Research Branch, CDC; Patrik Johansson, MD, Medical Officer (AHRQ); Therese Miller, DrPH, Task Order Officer (AHRQ); Janelle Guirguis-Blake, MD, USPSTF Program Director, and Elizabeth A. Edgerton, MD, MPH, Director of Clinical Prevention. Members of the USPSTF who served as leads for this project include Ned Calonge MD, MPH; Michael LeFevre, MD, MSPH; Carol Loveland-Cherry Ph.D., RN, FAAN; and Al Siu MD, MSPH. Investigators thank Nav Saloojee MD for helping in the selection of relevant reports, Tiffany Richards for assisting with the evidence tables, Raymond Daniel for retrieving the full reports and Chantelle Garritty who helped to coordinate the process. Investigators would also like to thank Isabella Steffensen and Christine Murray, who dedicated many long hours in the editing of the report and the appendices.