# 1996 Recommendations

B Recommendation:

In 1996, the Task Force recommended screening for elevated lead levels at least once at age 12 months in all children with identifiable risk factors, and in all children living in communities in which the prevalence of blood lead levels requiring individual intervention, including residential lead hazard control or chelation therapy, was high or was undefined. There was insufficient evidence, however, to recommend a specific community prevalence below which targeted screening could be substituted for universal screening.

C Recommendation:

The Task Force found insufficient evidence to recommend for or against routine screening for lead exposure in asymptomatic pregnant women.

C Recommendation:

The Task Force also found insufficient evidence to recommend for or against trying to prevent lead exposure by counseling families to control lead dust by repeated household cleaning, or to optimize caloric, iron, and calcium intake specifically to reduce lead absorption.