# References

1 DiGuiseppi C. Screening for Elevated Lead Levels in Childhood and Pregnancy. Guide to Clinical Preventive Services: Report of the U. S. Preventive Services Task Force. 2nd ed. Baltimore: Williams & Wilkins; 1996.
2 U. S. Preventive Services Task Force. Screening for Elevated Lead Levels in Childhood and Pregnancy: Recommendation. Guide to Clinical Preventive Services: Report of the U. S. Preventive Services Task Force. 2nd ed. Baltimore: Williams & Wilkins; 1996.
3 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force. A review of the process. Am J Prev Med. 2001;30(3S):21-35. [pmid: 11306229].
4 Bellinger DC, Hu H, Kalaniti K, et al. A pilot study of blood lead levels and neurobehavioral function in children living in Chennai, India. Int J Occup Environ Health. 2005;11(2):138-143. [pmid: 15875889].
5 Centers for Disease Control and Prevention. Blood Lead Levels - United States, 1999-2002. MMWR. 2005;54(20):513-516. [pmid: 15917736].
6 Brody DJ, Pirkle JL, Kramer RA, et al. Blood lead levels in the US population. Phase 1 of the Third National Health and Nutrition Examination Survey (NHANES III, 1988 to 1991) [erratum appears in JAMA 1995 Jul 12;274(2):130]. JAMA. 1994;272(4):277-283. [pmid: 8028140].
7 Fredeen DJ, Ehlinger EP, Cruikshank SH, Godes JR, Braun JE, Deinard AS. Lead levels among pregnant women in Hennepin County. Minnesota Medicine. 1992;75(11):29-32. [pmid: 1435646].
8 Flanigan GD Jr, Mayfield R, Blumenthal HT. Studies on lead exposure in patients of a neighborhood health center: Part II. A comparison of women of childbearing age and children. J Nat Med Assoc. 1992;84(1):23-27.
9 Stefanak MA, Bourguet CC, Benzies-Styka T. Use of the Centers for Disease Control and Prevention childhood lead poisoning risk questionnaire to predict blood lead elevations in pregnant women. Obstet Gynecol. 1996;87(2):209-212. [pmid: 8559525].
10 Crocetti AF, Mushak P, Schwartz J. Determination of numbers of lead-exposed women of childbearing age and pregnant women: An integrated summary of a report to the U.S. Congress on childhood lead poisoning. Environ Health Perspect. 1990;89:121-124. [pmid: 2088737].
11 Rhainds M, Levallois P, Dewailly E, Ayotte P. Lead, mercury, and organochlorine compound levels in cord blood in Quebec, Canada. Arch Environ Health. 1999;54(1):40-47. [pmid: 10025415].
12 Lee MG, Chun OK, Song WO. Determinants of the blood lead level of US women of reproductive age. J Am Coll Nutr. 2005;24(1):1-9. [pmid: 15670978].
13 Hu H, Hashimoto D, Besser M. Levels of lead in blood and bone of women giving birth in a Boston hospital. Arch Environ Health. 1996;51(1):52-58. [pmid: 8629865].
14 Needleman H. Lead poisoning. Annu Rev Med. 2004;55:209-222. [pmid: 14746518].
15 Centers for Disease Control and Prevention. Elevated blood lead levels in refugee children: New Hampshire, 2003-2004. MMWR. 2005;54(2):42-46. [pmid: 15660019].
16 centers for Disease Control and Prevention. CDC Recommendations for Lead Poisoning Prevention in Newly Arrived Refugee Children. Added 6.8.05; www.cdc.gov/nceh/lead/refugee%20recs.htm. Accessed June 2, 2005, 2005.
17 Surveillance for elevated blood lead levels among children: United States, 1997-2001. MMWR. 2003;52(SS10):1–21.
18 From the Centers for Disease Control and Prevention. Blood lead levels in young children—United States and selected states, 1996-1999. JAMA. 2001;285(3):286–287.
19 Children with elevated blood lead levels attributed to home renovation and remodeling activities—New York, 1993-1994. MMWR. 1997;45(51–52):1120–1123.
20 Sargent JD, Brown MJ, Freeman JL, Bailey A, Goodman D, Freeman DH Jr. Childhood lead poisoning in Massachusetts communities: its association with sociodemographic and housing characteristics. Am J Public Health. 1995;85(4):528-534. [pmid: 7702117].
21 Committee on Measuring Lead in Critical Populations NRC. Measuring lead exposure in infants, children, and other sensitive populations. Washington DC: National Academy Press. 1993.
22 Agency for Toxic Substances and Disease Registry. The nature and extent of lead poisoning in children in the United States: a report to Congress. Atlanta: Department of Health and Human Services. 1988;Publication no. DHHS-99-2966.
23 Department of Housing and Urban Development. Comprehensive and workable plan for the abatement of lead-based paint in privately owned housing. Report to Congress. Washington, DC. 1990;Publication no. HUD-PDR-1295.
24 Environmental Protection Agency. Reducing lead in drinking water: a benefit analysis. Washington, DC: Environmental Protection Agency. 1986;Office of Policy Planning and Evaluation.
25 Arnetz BB, Nicolich MJ. Modeling of environmental lead contributors to blood lead in human. Int Arch Occup Environ Health. 1990;62(5):397-402. [pmid: 2228261].
26 Jacobs DE, Clickner RP, Zhou JY, et al. The prevalence of lead-based paint hazards in U.S. housing. Environ Health Perspect. 2002;110(10).
27 Centers for Disease Control and Prevention NCfEH. Screening young children for lead poisoning: guidance for state and local health officials. Atlanta, GA: USDHHS; 1997.
28 Centers for Disease Control and Prevention Advisory Committee on Childhood Lead Poisoning. Recommendations for blood lead screening of young children enrolled in Medicaid: targeting a group at high risk. MMWR. 2000;49(RR-14):1-13.
29 Centers for Disease Control and Prevention Advisory Committee on Childhood Lead Poisoning. Preventing Lead Exposure in Young Children: A Housing-Based Approach to Primary Prevention of Lead Poisoning. Atlanta, GA: U. S. DHHS; 2004.
30 Centers for Disease C, Prevention. Blood lead levels in residents of homes with elevated lead in tap water—District of Columbia, 2004. MMWR. 2004;53(12):268-270. [pmid: 15057194].
31 Gardella C. Lead exposure in pregnancy: a review of the literature and argument for routine prenatal screening. Obstet Gynecol Surv. 2001;56(4):231-238. [pmid: 11285436].
32 Rhainds M, Levallois P. Effects of maternal cigarette smoking and alcohol consumption on blood lead levels of newborns. Am J Epidemiol. 1997;145(3):250-257. [pmid: 9012598].
33 Harville EW, Hertz-Picciotto I, Schramm M, et al. Factors influencing the difference between maternal and cord blood lead. Occup Environ Med. 2005;62(4):263-269. [pmid: 15778260].
34 Klitzman S, Sharma A, Nicaj L, Vitkevich R, Leighton J. Lead poisoning among pregnant women in New York City: risk factors and screening practices. J Urban Health. 2002;79(2):225-237. [pmid: 12023498].
35 Lanphear BP, Dietrich KN, Berger O. Prevention of lead toxicity in US children. Ambul Pediatr. 2003;3(1):27-36. [pmid: 12540251].
36 Fatal pediatric lead poisoning—New Hampshire, 2000. MMWR. 2001;50(22):457–459.
37 Baghurst PA, McMichael AJ, Wigg NR, et al. Environmental exposure to lead and children's intelligence at the age of seven years. The Port Pirie Cohort Study. N Engl J Med. 1992;327(18):1279-1284. [pmid: 1383818].
38 Cooney G, Bell A, Stravou C. Low level exposure to lead and neurobehavioural development: the Sydney Study at seven years. Proceedings of Heavy Metals in the Environment Conference, Edinburgh. 1991;Farmer JG, ed.(1):16–19.
39 Bellinger DC, Stiles KM, Needleman HL. Low-level lead exposure, intelligence and academic achievement: a long-term follow-up study. Pediatrics. 1992;90(6):855-861. [pmid: 1437425].
40 Dietrich KN, Berger OG, Succop PA, Hammond PB, Bornschein RL. The developmental consequences of low to moderate prenatal and postnatal lead exposure: intellectual attainment in the Cincinnati Lead Study Cohort following school entry. Neurotoxicol Teratol. 1993;15(1):37-44. [pmid: 8459787].
41 Ernhart CB, Morrow-Tlucak M, Wolf AW, Super D, Drotar D. Low level lead exposure in the prenatal and early preschool periods: intelligence prior to school entry. Neurotoxicol Teratol. 1989;11(2):161-170. [pmid: 2733654].
42 Wasserman GA, Graziano JH, Factor-Litvak P, et al. Consequences of lead exposure and iron supplementation on childhood development at age 4 years. Neurotoxicol Teratol. 1994;16(3):233-240. [pmid: 7523846].
43 Wolf AW, Jimenez E, Lozoff B. No evidence of developmental III effects of low-level lead exposure in a developing country. J Dev Behav Pediatr. 1994;15(4):224-231. [pmid: 7528225].
44 Pocock SJ, Smith M, Baghurst P. Environmental lead and children's intelligence: a systematic review of the epidemiological evidence. BMJ. 1994;309(6963):1189-1197. [pmid: 7987149].
45 Chen A, Dietrich K, Ware JH, Radcliffe J, Rogan W. IQ and blood lead from 2 to 7 years of age: are the effects in older children the residual of high blood lead concentrations in 2-year-olds?. Environ Health Perspect. 2005;113(5):597-601. [pmid: 15866769].
46 Needleman HL, Gatsonis CA. Low-level lead exposure and the IQ of children. A meta-analysis of modern studies. JAMA. 1990;263(5):673-678. [pmid: 2136923].
47 Winneke G, Brockhaus A, Ewers U, Kramer U, Neuf M. Results from the European multicenter study on lead neurotoxicity in children: implications for risk assessment. Neurotoxicol Teratol. 1990;12(5):553-559. [pmid: 2247047].
48 Winneke G, Beginn U, Ewert T, et al. Comparing the effects of perinatal and later childhood lead exposure on neuropsychological outcome. Environ Res. 1985;38(1):155-167. [pmid: 4076104].
49 Winneke G, Kramer U, Brockhaus A, et al. Neuropsychological studies in children with elevated tooth-lead concentrations. II. Extended study. Int Arch Occup Environ Health. 1983;51(3):231-252. [pmid: 6852930].
50 Winneke G, Brockhaus A, Collet W, Kramer U. Modulation of lead-induced performance deficit in children by varying signal rate in a serial choice reaction task. Neurotoxicol Teratol. 1989;11(6):587-592. [pmid: 2626150].
51 Hatzakis A, Kokkevi A, Katsouyanni K, et al. Psychometric intelligence and attentional performance deficits in lead-exposed children. Proceedings of the International Conference: heavy metals in the environment. 1987;1:204-209.
52 Wigg NR. Low-level lead exposure and children. J Paediatr Child Health. 2001;37(5):423-425. [pmid: 11885702].
53 Bellinger DC. Lead. Pediatrics. 2004;113(4 Suppl):1016-1022. [pmid: 15060194].
54 Otto DA, Fox DA. Auditory and visual dysfunction following lead exposure. Neurotoxicology. 1993;14(23):191-207. [pmid: 8247393].
55 Cory-Slechta D. The behavioral toxicity of lead: problems and perspectives. Adv Behav Pharmacol. 1984;4:211-255.
56 Rice D. Lead-induced changes in learning: evidence for behavioral mechanisms from experimental animal studies. Neurotoxicology. 1993;14:167-178. [pmid: 8247391].
57 Koller K, Brown T, Spurgeon A, Levy L. Recent developments in low-level lead exposure and intellectual impairment in children. Environ Health Perspect. 2004;112(9):987-994. [pmid: 15198918].
58 Canfield RL, Gendle MH, Cory-Slechta DA. Impaired neuropsychological functioning in lead-exposed children. Dev Neuropsychol. 2004;26(1):513-540. [pmid: 15276907].
59 Lanphear BP, Dietrich K, Auinger P, Cox C. Cognitive deficits associated with blood lead concentrations <10 microg/dL in US children and adolescents. Public Health Rep. 2000;115(6):521-529. [pmid: 11354334].
60 Chiodo LM, Jacobson SW, Jacobson JL. Neurodevelopmental effects of postnatal lead exposure at very low levels. Neurotoxicol Teratol. 2004;26(3):359-371. [pmid: 15113598].
61 Lanphear B, Hornung R, Khoury J, et al. Low-level environmental lead exposure and children's intellectual function: an international pooled analysis. Environ Health Perspect. 2005;113:894-899. [pmid: 16002379].
62 Ernhart CB, Wolf AW, Kennard MJ, Erhard P, Filipovich HF, Sokol RJ. Intrauterine exposure to low levels of lead: the status of the neonate. Arch Environ Health. 1986;41(5):287-291. [pmid: 3800431].
63 McMichael AJ, Vimpani GV, Robertson EF, Baghurst PA, Clark PD. The Port Pirie cohort study: maternal blood lead and pregnancy outcome. J Epidemiol Community Health. 1986;40(1):18-25. [pmid: 3711766].
64 Bellinger D, Leviton A, Rabinowitz M, Allred E, Needleman H, Schoenbaum S. Weight gain and maturity in fetuses exposed to low levels of lead. Environ Res. 1991;54(2):151-158. [pmid: 2029876].
65 Murphy MJ, Graziano JH, Popovac D, et al. Past pregnancy outcomes among women living in the vicinity of a lead smelter in Kosovo, Yugoslavia. Am J Public Health. 1990;80(1):33-35. [pmid: 2293800].
66 Lindbohm ML, Sallmen M, Anttila A, Taskinen H, Hemminki K. Paternal occupational lead exposure and spontaneous abortion. Scand J Work Environ Health. 1991;17(2):95-103. [pmid: 2047818].
67 Laudanski T, Sipowicz M, Modzelewski P, et al. Influence of high lead and cadmium soil content on human reproductive outcome. Int J Gynaecol Obstet. 1991;36(4):309-315. [pmid: 1684764].
68 Dietrich KN, Krafft KM, Bornschein RL, et al. Low-level fetal lead exposure effect on neurobehavioral development in early infancy. Pediatrics. 1987;80(5):721-730. [pmid: 2444921].
69 Factor-Litvak P, Graziano JH, Kline JK, et al. A prospective study of birth weight and length of gestation in a population surrounding a lead smelter in Kosovo, Yugoslavia. Int J Epidemiol. 1991;20(3):722-728. [pmid: 1955258].
70 Milman N, Christensen JM, Ibsen KK. Blood lead and erythrocyte zinc protoporphyrin in mothers and newborn infants. Eur J Pediatr. 1988;147(1):71-73. [pmid: 3338481].
71 Ernhart CB. A critical review of low-level prenatal lead exposure in the human: 1. Effects on the fetus and newborn. Reprod Toxicol. 1992;6(1):9-19. [pmid: 1562804].
72 Baghurst PA, Robertson EF, Oldfield RK, et al. Lead in the placenta, membranes, and umbilical cord in relation to pregnancy outcome in a lead-smelter community. Environ Health Perspect. 1991;90:315-320. [pmid: 2050080].
73 Andrews KW, Savitz DA, Hertz-Picciotto I. Prenatal lead exposure in relation to gestational age and birth weight: a review of epidemiologic studies. Am J Ind Med. 1994;26(1):13-32. [pmid: 8074121].
74 Rothenberg SJ, Schnaas L, Perroni E, Hernandez RM, Martinez S, Hernandez C. Pre- and postnatal lead effect on head circumference: a case for critical periods. Neurotoxicol Teratol. 1999;21(1):1-11. [pmid: 10023796].
75 Gonzalez-Cossio T, Peterson KE, Sanin LH, et al. Decrease in birth weight in relation to maternal bone-lead burden. Pediatrics. 1997;100(5):856-862. [pmid: 9346987].
76 Emory E, Pattillo R, Archibold E, Bayorh M, Sung F. Neurobehavioral effects of low-level lead exposure in human neonates. Am J Obstet Gynecol. 1999;181(1).
77 Emory E, Ansari Z, Pattillo R, Archibold E, Chevalier J. Maternal blood lead effects on infant intelligence at age 7 months. Am J Obstet Gynecol. 2003;188(4).
78 Rothenberg SJ, Poblano A, Schnaas L. Brainstem auditory evoked response at five years and prenatal and postnatal blood lead. Neurotoxicol Teratol. 2000;22(4):503-510. [pmid: 10974588].
79 Rothenberg SJ, Schnaas L, Salgado-Valladares M, et al. Increased ERG a- and b-wave amplitudes in 7- to 10-year-old children resulting from prenatal lead exposure. Invest Ophthalmol Vis Sci. 2002;43(6):2036-2044. [pmid: 12037016].
80 Chisolm JJ Jr. The use of chelating agents in the treatment of acute and chronic lead intoxication in childhood. J Pediatr. 1968;73(1):1-38. [pmid: 4969284].
81 Pueschel SM, Kopito L, Schwachman H. Children with an increased lead burden. A screening and follow-up study. JAMA. 1972;222(4):462-466. [pmid: 4677833].
82 Nuyts GD, Daelemans RA, Jorens PG, Elseviers MM, Van de Vyver FL, De Broe ME. Does lead play a role in the development of chronic renal disease?. Nephrol Dial Transplant. 1991;6(5):307-315. [pmid: 1870746].
83 Hu H. A 50-year follow-up of childhood plumbism. Hypertension, renal function, and hemoglobin levels among survivors. Am J Dis Child. 1991;145(6):681-687. [pmid: 2035497].
84 Bernard AM, Vyskocil A, Roels H, Kriz J, Kodl M, Lauwerys R. Renal effects in children living in the vicinity of a lead smelter. Environ Res. 1995;68(2):91-95. [pmid: 7601077].
85 Fels LM, Wunsch M, Baranowski J, et al. Adverse effects of chronic low level lead exposure on kidney function—a risk group study in children. Nephrol Dial Transplant. 1998;13(9):2248-2256. [pmid: 9761504].
86 Grandjean P, Hollnagel H, Hedegaard L, Christensen JM, Larsen S. Blood lead-blood pressure relations: alcohol intake and hemoglobin as confounders. Am J Epidemiol. 1989;129(4):732-739. [pmid: 2923121].
87 Elwood PC, Yarnell JW, Oldham PD, et al. Blood pressure and blood lead in surveys in Wales. Am J Epidemiol. 1988;127(5):942-945. [pmid: 3358414].
88 Schwartz J. Lead, blood pressure, and cardiovascular disease in men and women. Environ Health Perspect. 1991;91:71-75. [pmid: 1828226].
89 Moller L, Kristensen TS. Blood lead as a cardiovascular risk factor. Am J Epidemiol. 1992;136(9):1091-1100. [pmid: 1462969].
90 Dolenc P, Staessen JA, Lauwerys RR, Amery A. Short report: low-level lead exposure does not increase the blood pressure in the general population. Cadmibel Study Group. J Hypertens. 1993;11(5):589-593. [pmid: 8390532].
91 Hense HW, Filipiak B, Keil U. The association of blood lead and blood pressure in population surveys. Epidemiology. 1993;4:173-179. [pmid: 8452907].
92 Rabinowitz M, Bellinger D, Leviton A, Needleman H, Schoenbaum S. Pregnancy hypertension, blood pressure during labor, and blood lead levels. Hypertension. 1986;10(4):447-451. [pmid: 3653974].
93 Selbst SM, Sokas RK, Henretig FM, Weller SC, Tershakovec AM. The effect of blood lead on blood pressure in children. J Environ Pathol Toxicol Oncol. 1993;12(4):213-218. [pmid: 8189378].
94 Schwartz J, Angle C, Pitcher H. Relationship between childhood blood lead levels and stature. Pediatrics. 1986;77(3):281-288. [pmid: 3951909].
95 Frisancho AR, Ryan AS. Decreased stature associated with moderate blood lead concentrations in Mexican-American children. Am J Clin Nutr. 1991;54(3):516-519. [pmid: 1877508].
96 Shukla R, Dietrich KN, Bornschein RL, Berger O, Hammond PB. Lead exposure and growth in the early preschool child: a follow-up report from the Cincinnati Lead Study. Pediatrics. 1991;88(5):886-892. [pmid: 1945627].
97 Greene T, Ernhart CB. Prenatal and preschool age lead exposure: relationship with size. Neurotoxicol Teratol. 1991;13(4):417-427. [pmid: 1921921].
98 Rothenberg SJ, Manalo M, Jiang J, et al. Blood lead level and blood pressure during pregnancy in South Central Los Angeles. Arch Environ Health. 1999;54(6):382-389. [pmid: 10634227].
99 Rothenberg SJ, Kondrashov V, Manalo M, et al. Increases in hypertension and blood pressure during pregnancy with increased bone lead levels. Am J Epidemiol. 2002;156(12):1079-1087. [pmid: 12480651].
100 Magri J, Sammut M, Savona-Ventura C. Lead and other metals in gestational hypertension. Int J Gynaecol Obstet. 2003;83(1):29-36. [pmid: 14511869].
101 Dawson EB, Evans DR, Kelly R, Van Hook JW. Blood cell lead, calcium, and magnesium levels associated with pregnancy-induced hypertension and preeclampsia. Biol Trace Elem Res. 2000;74(2):107-116. [pmid: 11051585].
102 Jacobson BE, Lockitch G, Quigley G. Improved sample preparation for accurate determination of low concentrations of lead in whole blood by graphite furnace analysis. Clin Chem. 1991;37(4):515-519. [pmid: 2015663].
103 Parsons P, Raciti KA, Esernio-Jenssen D. Evaluation and improvement of sample collection procedures for the determination of blood lead. Third semi-annual report to the Center for Environmental Health and Injury Control. 1993;Center for Disease Control and Prevention (Atlanta: Centers for Disease Control and Prevention).
104 Schlenker TL, Fritz CJ, Mark D, et al. Screening for pediatric lead poisoning. Comparability of simultaneously drawn capillary and venous blood samples. JAMA. 1994;271(17):1346-1348. [pmid: 8158820].
105 Schonfeld DJ, Cullen MR, Rainey PM, et al. Screening for lead poisoning in an urban pediatric clinic using samples obtained by fingerstick. Pediatrics. 1994;94(2 Pt 1):174-179. [pmid: 8036069].
106 Lyngbye T, Jorgensen PJ, Grandjean P, Hansen ON. Validity and interpretation of blood lead levels: a study of Danish school children. Scand J Clin Lab Invest. 1990;50(4):441-449. [pmid: 2392655].
107 Schonfeld DJ, Rainey PM, Cullen MR, Showalter DR, Cicchetti DV. Screening for lead poisoning by fingerstick in suburban pediatric practices. Arch Pediatr Adolesc Med. 1995;149(4):447-450. [pmid: 7704175].
108 Parsons PJ. Monitoring human exposure to lead: an assessment of current laboratory performance for the determination of blood lead. Environ Res. 1992;57(2):149-162. [pmid: 1568437].
109 Blumenthal HT, Flanigan GD Jr, Mayfield R. Studies on lead exposure in patients of a neighborhood health center: Part I: Pediatric patients. J Natl Med Assoc. 1991;83:1065-1072. [pmid: 1813636].
110 Mahaffey KR, Annest JL. Association of erythrocyte protoporphyrin with blood lead level and iron status in the second National Health and Nutrition Examination Survey, 1976-1980. Environ Res. 1986;41(1):327-338. [pmid: 3489614].
111 Debaun MR, Sox HC. Setting the optimal erythrocyte protoporphyrin screening decision threshold for lead poisoning: a decision analytic approach. Pediatrics. 1991;88:121-131. [pmid: 2057248].
112 Parsons PJ, Reilly AA, Hussain A. Observational study of erythrocyte protoporphyrin screening test for detecting low lead exposure in children: impact of lowering the blood lead action threshold. Clin Chem. 1991;37(2):216-225. [pmid: 1993327].
113 McElvaine MD, Orbach HG, Binder S, Blanksma LA, Maes EF, Krieg RM. Evaluation of the erythrocyte protoporphyrin test as a screen for elevated blood lead levels. J Pediatr. 1991;119(4):548-550. [pmid: 1919884].
114 Leung FY, Bradley C, Pellar TG. Reference intervals for blood lead and evaluation of zinc protoporphyrin as a screening test for lead toxicity. Clin Biochem. 1993;26(6):491-496. [pmid: 8124865].
115 Rolfe PB, Marcinak JF, Nice AJ, Williams RH. Use of zinc protoporphyrin measured by the Protofluor-Z hematofluorometer in screening children for elevated blood lead levels. Am J Dis Child. 1993;147(1):66-68. [pmid: 8418602].
116 Marcus AH, Schwartz J. Dose-response curves for erythrocyte protoporphyrin vs. blood lead: effects of iron status. Environ Res. 1987;44(2):221-227. [pmid: 3691443].
117 Guthrie R, Orfanos A, Widger K, Luskin B, Francemone C, Nadler D. Screening suburban/rural children for lead exposure, iron deficiency. Am J Public Health. 1988;78(7):856-857. [pmid: 3381973].
118 Tejeda DM, Wyatt DD, Rostek BR, Solomon WB. Do questions about lead exposure predict elevated lead levels?. Pediatrics. 1994;93(2):192-194. [pmid: 8121730].
119 Binns HJ, LeBailly SA, Poncher J, Kinsella TR, Saunders SE. Is there lead in the suburbs? Risk assessment in Chicago suburban pediatric practices. Pediatric Practice Research Group. Pediatrics. 1994;93(2):164-171. [pmid: 8121725].
120 Nordin JD, Rolnick SJ, Griffin JM. Prevalence of excess lead absorption and associated risk factors in children enrolled in a Midwestern health maintenance organization. Pediatrics. 1994;93(2):172-177. [pmid: 8121726].
121 Schaffer SJ, Szilagyi PG, Weitzman M. Lead poisoning risk determination in an urban population through the use of a standardized questionnaire. Pediatrics. 1994;93(2):159-163. [pmid: 8121724].
122 Rooney BL, Hayes EB, Allen BK, Strutt PJ. Development of a screening tool for prediction of children at risk for lead exposure in a Midwestern clinical setting. Pediatrics. 1994;93(2):183-187. [pmid: 8121728].
123 Striph KB. Prevalence of lead poisoning in a suburban practice. J Fam Pract. 1995;41(1):65-71. [pmid: 7798067].
124 Centers for Disease Control and Prevention. Preventing lead poisoning in young children. A statement by the Centers for Disease Control - October 1991. Atlanta: Department of Health and Human Services; 1991.
125 France EK, Gitterman BA, Melinkovich P, Wright RA. The accuracy of a lead questionnaire in predicting elevated pediatric blood lead levels. Arch Pediatr Adolesc Med. 1996;150(9):958-963. [pmid: 8790128].
126 Kazal LA Jr. The failure of CDC screening questionnaire to efficiently detect elevated lead levels in a rural population of children. J Fam Pract. 1997;45(6):515-518. [pmid: 9420588].
127 Muniz MA, Dundas R, Mahoney MC. Evaluation of a childhood lead questionnaire in predicting elevated blood lead levels in a rural community. J Rural Health. 2003;19(1):15-19. [pmid: 12585770].
128 Robin LF, Beller M, Middaugh JP. Statewide assessment of lead poisoning and exposure risk among children receiving Medicaid services in Alaska. Pediatrics. 1997;99(4).
129 Schaffer SJ, Kincaid MS, Endres N, Weitzman M. Lead poisoning risk determination in a rural setting. Pediatrics. 1996;97(1):84-90. [pmid: 8545231].
130 Sargent JD, Dalton M, Klein RZ. Diagnostic testing unwarranted for children with blood lead 10 to 14 microg/dL. Pediatrics. 1999;103(4).
131 Lanphear B, Hornung R, Ho M. Screening housing to prevent lead toxicity in children. Public Health Rep. 2005;120:305-310. [pmid: 16134573].
132 McCusker J. Longitudinal changes in blood lead level in children and their relationship to season, age, and exposure to paint or plaster. Am J Public Health. 1979;69(4):348-352. [pmid: 426160].
133 Reigart JR, Whitlock NH. Longitudinal observations of the relationship between free erythrocyte porphyrins and whole blood lead. Pediatrics. 1976;57(1):54-59. [pmid: 1246505].
134 Sachs HK, Blanksma LA, Murray EF, O'Connell MJ. Ambulatory treatment of lead poisoning: report of 1,155 cases. Pediatrics. 1970;46(3):389-396. [pmid: 4989395].
135 Sachs HK. Effect of a screening program on changing patterns of lead poisoning. Environ Health Perspect. 1974;7:41-45. [pmid: 4831147].
136 Browder A, Joselow M, Louria DB, Lavenhar M, Foster J. Evaluation of screening programs for childhood lead poisoning by analysis of hospital admissions. Am J Public Health. 1974;64(9):914-915. [pmid: 4425003].
137 Rogan W. The Treatment of Lead-exposed Children (TLC) trial: design and recruitment for a study of the effect of oral chelation on growth and development in toddlers. Paediatr Perinat Epidemiol. 1998;12:313-333. [pmid: 9690266].
138 Rogan WJ, Dietrich KN, Ware JH, et al. The effect of chelation therapy with succimer on neuropsychological development in children exposed to lead. N Engl J Med. 2001;344(19):1421-1426. [pmid: 11346806].
139 Liu X, Dietrich KN, Radcliffe J, Ragan NB, Rhoads GG, Rogan WJ. Do children with falling blood lead levels have improved cognition?. Pediatrics. 2002;110(4):787-791. [pmid: 12359796].
140 Dietrich KN, Ware JH, Salganik M, et al. Effect of chelation therapy on the neuropsychological and behavioral development of lead-exposed children after school entry. Pediatrics. 2004;114(1):19-26. [pmid: 15231903].
141 Peterson KE, Salganik M, Campbell C, et al. Effect of succimer on growth of preschool children with moderate blood lead levels. Environ Health Perspect. 2004;112(2):233-237. [pmid: 14754579].
142 Ruff HA, Bijur PE, Markowitz M, Ma YC, Rosen JF. Declining blood lead levels and cognitive changes in moderately lead-poisoned children. JAMA. 1993;269(13):1641-1646. [pmid: 8455297].
143 Markowitz ME, Bijur PE, Ruff H, Rosen JF. Effects of calcium disodium versenate (CaNa2EDTA) chelation in moderate childhood lead poisoning. Pediatrics. 1993;92(2):265-271. [pmid: 8337028].
144 Rogan W. Safety and efficacy of succimer in toddlers with blood lead levels of 20–44 ug/dL. Pediatr Res. 2000;48(5):593-599. [pmid: 11044477].
145 Graziano JH, Lolacono NJ, Moulton T, Mitchell ME, Slavkovich V, Zarate C. Controlled study of meso-2,3-dimercaptosuccinic acid for the management of childhood lead intoxication. J Pediatr. 1992;120(1):133-139. [pmid: 1309865].
146 Graziano JH, Lolacono NJ, Meyer P. Dose-response study of oral 2,3-dimercaptosuccinic acid in children with elevated blood lead concentrations. J Pediatr. 1988;113(4):751-757. [pmid: 2845043].
147 Shannon M, Graef J, Lovejoy FH Jr. Efficacy and toxicity of D-penicillamine in low-level lead poisoning. J Pediatr. 1988;112(5):799-804. [pmid: 3361395].
148 Liebelt EL, Shannon M, Graef JW. Efficacy of oral meso-2,3-dimercaptosuccinic acid therapy for low-level childhood plumbism. J Pediatr. 1994;124(2):313-317. [pmid: 8301445].
149 Shannon M, Grace A, Graef JW. Use of penicillamine in children with small lead burdens. N Engl J Med. 1989;321(14):979-980. [pmid: 2779624].
150 Besunder JB, Anderson RL, Super DM. Short-term efficacy of oral dimercaptosuccinic acid in children with low to moderate lead intoxication. Pediatrics. 1995;96(4 Pt 1):683-687. [pmid: 7567330].
151 O'Connor ME, Rich D. Children with moderately elevated lead levels: is chelation with DMSA helpful?. Clin Pediatr. 1999;38(6):325-331.
152 Chisolm JJ Jr. Safety and efficacy of meso-2,3-dimercaptosuccinic acid (DMSA) in children with elevated blood lead concentrations. J Toxicol Clin Toxicol. 2000;38(4):365-375. [pmid: 10930052].
153 Moel DI, Sachs HK, Drayton MA. Slow, natural reduction in blood lead level after chelation therapy for lead poisoning in childhood. Am J Dis Child. 1986;140(9):905-908. [pmid: 3739998].
154 Chisolm JJ Jr. Chelation therapy in children with subclinical plumbism. Pediatrics. 1974;53(3):441-443. [pmid: 4205583].
155 Vitale LF, Rosalinas-Bailon A, Folland D, Brennan JF, McCormick B. Oral penicillamine therapy for chronic lead poisoning in children. J Pediatr. 1973;83(6):1041-1045. [pmid: 4757518].
156 Marcus SM. Experience with D-penicillamine in treating lead poisoning. Vet Hum Toxicol. 1982;24(1):18-20. [pmid: 7058627].
157 Markowitz ME, Bijur PE, Ruff HA, Balbi K, Rosen JF. Moderate lead poisoning: trends in blood lead levels in unchelated children. Environ Health Perspect. 1996;104(9):968-972. [pmid: 8899376].
158 Office of Policy Development and Research Department of Housing and Urban Development. Lead-based paint abatement demonstration (FHA). Washington, DC: Department of Housing and Urban Development. 1991;(Publication no. HUD-1316-PDR).
159 Farfel MR, Chisolm JJ Jr, Rohde CA. The longer-term effectiveness of residential lead paint abatement. Environ Res. 1994;66(2):217-221. [pmid: 8055843].
160 Clark S, Grote J, Wilson J, et al. Occurrence and determinants of increases in blood lead levels in children shortly after lead hazard control activities. Environ Res. 2004;96(2):196-205. [pmid: 15325880].
161 Rhoads G, Ettinger A, Weisel C, et al. The effect of dust lead control on blood lead in toddlers: a randomized trial. Pediatrics. 1999;103(3):551-555. [pmid: 10049955].
162 Taha T, Kanarek MS, Schultz BD, Murphy A. Low-cost household paint abatement to reduce children's blood lead levels. Environ Res. 1999;81(4):334-338. [pmid: 10581111].
163 Aschengrau A, Hardy S, Mackey P, Pultinas D. The impact of low technology lead hazard reduction activities among children with mildly elevated blood lead levels. Environ Res. 1998;79(1):41-50. [pmid: 9756679].
164 Leighton J, Klitzman S, Sedlar S, Matte T, Cohen NL. The effect of lead-based paint hazard remediation on blood lead levels of lead poisoned children in New York City. Environ Res. 2003;92(3):182-190. [pmid: 12804514].
165 Haynes E, Lanphear BP, Tohn E, Farr N, Rhoads GG. The effect of interior lead hazard controls on children's blood lead concentrations: a systematic evaluation. Environ Health Perspect. 2002;110(1):103-107. [pmid: 11781171].
166 Yiin LM, Lioy PJ, Rhoads GG. Impact of home carpets on childhood lead intervention study. Environ Res. 2003;92(2):161-165. [pmid: 12854696].
167 Campbell C, Schwarz DF, Rich D, Dockery DW. Effect of a follow-up professional home cleaning on serial dust and blood lead levels of urban children. Arch Environ Health. 2003;58(12):771-780. [pmid: 15859512].
168 Swindell SL, Charney E, Brown MJ, Delaney J. Home abatement and blood lead changes in children with class III lead poisoning. Clin Pediatr. 1994;33(9):536-541.
169 Brown MJ, Gardner J, Sargent JD, Swartz K, Hu H, Timperi R. The effectiveness of housing policies in reducing children's lead exposure. Am J Public Health. 2001;91(4):621-624. [pmid: 11291376].
170 Galke W, Clark S, Wilson J, et al. Evaluation of the HUD lead hazard control grant program: early overall findings. Environ Res. 2001;86(2):149-156. [pmid: 11437461].
171 Strauss W, Pivetz T, Ashley P, Menkedick J, Slone E, Cameron S. Evaluation of lead hazard control treatments in four Massachusetts communities through analysis of blood-lead surveillance data. Environ Res 2005;in press.
172 Foster JD, Louria DB, Stinson L. Influence of documented lead poisoning on environmental modification programs in Newark, New Jersey. Arch Environ Health. 1979;34(5):368-371. [pmid: 496435].
173 Weitzman M, Aschengrau A, Bellinger D, Jones R, Hamlin JS, Beiser A. Lead-contaminated soil abatement and urban children's blood lead levels. JAMA. 1993;269(13):1647-1654. [pmid: 8455298].
174 Environmental Protection Agency. Three city urban soil lead abatement demonstration project (fact sheet). Washington, DC: Environmental Protection Agency. 1992;(Publication no. 9355.4-10FSa).
175 Farrell KP, Brophy MC, Chisolm JJ Jr, Rohde CA, Strauss WJ. Soil lead abatement and children's blood lead levels in an urban setting. Am J Public Health. 1998;88(12):1837-1839. [pmid: 9842383].
176 Charney E, Kessler B, Farfel M, Jackson D. Childhood lead poisoning. A controlled trial of the effect of dust-control measures on blood lead levels. N Engl J Med. 1983;309(18):1089-1093. [pmid: 6353234].
177 Jordan CM, Yust BL, Robison LL, Hannan P, Deinard AS. A randomized trial of education to prevent lead burden in children at high risk for lead exposure: efficacy as measured by blood lead monitoring. Environ Health Perspect. 2003;111(16):1947-1951. [pmid: 14644671].
178 Lanphear BP, Howard C, Eberly S, et al. Primary prevention of childhood lead exposure: A randomized trial of dust control. Pediatrics. 1999;103(4 Pt 1):772-777. [pmid: 10103301].
179 Schultz B, Pawel D, Murphy A. A retrospective examination of in-home educational visits to reduce childhood lead levels. Environ Res. 1999;80(4):364-368. [pmid: 10330310].
180 Kimbrough R, LeVois M, Webb D. Survey of lead exposure around a closed lead smelter. Pediatrics. 1995;95(4):550-554. [pmid: 7700757].
181 Porru S, Donato F, Apostoli P, Coniglio L, Duca P, Alessio L. The utility of health education among lead workers: the experience of one program. Am J Ind Med. 1993;23(3):473-481. [pmid: 8503465].
182 Aschengrau A, Beiser A, Bellinger D, Copenhafer D, Weitzman M. The impact of soil lead abatement on urban children's blood lead levels: phase II results from the Boston Lead-In-Soil Demonstration Project. Environ Res. 1994;67(2):125-148. [pmid: 7982389].
183 Aschengrau A, Beiser A, Bellinger D, Copenhafer D, Weitzman M. Residential lead-based-paint hazard remediation and soil lead abatement: their impact among children with mildly elevated blood lead levels. Am J Public Health. 1997;87(10):1698-1702. [pmid: 9357358].
184 Lanphear BP, Succop P, Roda S, Henningsen G. The effect of soil abatement on blood lead levels in children living near a former smelting and milling operation. Public Health Rep. 2003;118(2):83-91. [pmid: 12690062].
185 Dalton MA, Sargent JD, O'Connor GT, Olmstead EM, Klein RZ. Calcium and phosphorus supplementation of iron-fortified infant formula: no effect on iron status of healthy full-term infants. Am J Clin Nutr. 1997;65(4):921-926. [pmid: 9094873].
186 Gallicchio L, Scherer RW, Sexton M. Influence of nutrient intake on blood lead levels of young children at risk for lead poisoning. Environ Health Perspect. 2002;110(12).
187 Hammad TA, Sexton M, Langenberg P. Relationship between blood lead and dietary iron intake in preschool children. A cross-sectional study. Ann Epidemiol. 1996;6(1):30-33. [pmid: 8680621].
188 Lucas SR, Sexton M, Langenberg P. Relationship between blood lead and nutritional factors in preschool children: a cross-sectional study. Pediatrics. 1996;97(1):74-78. [pmid: 8545229].
189 Markowitz ME, Sinnett M, Rosen JF. A randomized trial of calcium supplementation for childhood lead poisoning. Pediatrics. 2004;113(1 Pt 1).
190 Sargent JD, Dalton MA, O'Connor GT, Olmstead EM, Klein RZ. Randomized trial of calcium glycerophosphate-supplemented infant formula to prevent lead absorption. Am J Clin Nutr. 1999;69(6):1224-1230. [pmid: 10357743].
191 Schell LM, Denham M, Stark AD, Ravenscroft J, Parsons P, Schulte E. Relationship between blood lead concentration and dietary intakes of infants from 3 to 12 months of age. Environ Res. 2004;96(3):264-273. [pmid: 15364593].
192 Schell LM, Denham M, Stark AD, et al. Maternal blood lead concentration, diet during pregnancy, and anthropometry predict neonatal blood lead in a socioeconomically disadvantaged population. Environ Health Perspect. 2003;111(2):195-200. [pmid: 12573905].
193 Simon JA, Hudes ES. Relationship of ascorbic acid to blood lead levels. JAMA. 1999;281(24):2289-2293. [pmid: 10386552].
194 Zierold KM, Anderson H. Trends in blood lead levels among children enrolled in the Special Supplemental Nutrition Program for Women, Infants, and Children from 1996 to 2000. Am J Public Health. 2004;94(9):1513-1515. [pmid: 15333304].
195 Lanphear BP, Hornung R, Ho M, Howard CR, Eberly S, Knauf K. Environmental lead exposure during early childhood. J Pediatr. 2002;140(1):40-47. [pmid: 11815762].
196 Haynes E, Kalkwarf H, Hornung R, et al. Vitamin D Fok1 polymorphism and blood lead concentration in children. Environ Health Perspect. 2003;111:1665-1669. [pmid: 14527848].
197 Bellinger D. Teratogen Update: Lead and Pregnancy. Birth Defects Research. 2004;(Part A) 73:409–420.
198 Glotzer DE, Bauchner H. Management of childhood lead poisoning: a survey. Pediatrics. 1992;89:614-618. [pmid: 1313555].
199 Markowitz ME, Rosen JF. Need for the lead mobilization test in children with lead poisoning. J Pediatr. 1991;119(2):305-310. [pmid: 1907320].
200 Farfel MR, Chisolm JJ Jr. Health and environmental outcomes of traditional and modified practices for abatement of residential lead-based paint. Am J Public Health. 1990;80(10):1240-1245. [pmid: 2136329].
201 Amitai Y, Brown MJ, Graef JW, Cosgrove E. Residential deleading: effects on the blood lead levels of lead-poisoned children. Pediatrics. 1991;88(5):893-897. [pmid: 1945628].
202 Amitai Y, Graef JW, Brown MJ, Gerstle RS, Kahn N, Cochrane PE. Hazards of ‘deleading’ homes of children with lead poisoning. Am J Dis Child. 1987;141(7):758-760. [pmid: 2438931].
203 Rey-Alvarez S, Menke-Hargrave T. Deleading dilemma: pitfall in the management of childhood lead poisoning. Pediatrics. 1987;79(2):214-217. [pmid: 2433676].
204 Feldman RG. Urban lead mining: lead intoxication among deleaders. N Engl J Med. 1978;298(20):1143-1145. [pmid: 643036].
205 Chisolm JJ Jr. Treatment of acute lead intoxication—choice of chelating agents and supportive therapeutic measures. Clin Toxicol. 1970;3(4):527-540. [pmid: 4999705].
206 Moel DI, Kumar K. Reversible nephrotoxic reactions to a combined 2,3-dimercapto-1-propanol and calcium disodium ethylenediaminetetraacetic acid regimen in asymptomatic children with elevated blood lead levels. Pediatrics. 1982;70(2):259-262. [pmid: 7099793].
207 Shannon MW, Townsend MK. Adverse effects of reduced-dose d-penicillamine in children with mild-to-moderate lead poisoning. Ann Pharmacother. 2000;34(1):15-18. [pmid: 10669180].
208 Mann KV, Travers JD. Succimer, an oral lead chelator. Clin Pharm. 1991;10(12):914-922. [pmid: 1663439].
209 Lane WG, Kemper AR. American College of Preventive M. American College of Preventive Medicine Practice Policy Statement. Screening for elevated blood lead levels in children. Am J Prev Med. 2001;20(1):78-82. [pmid: 11137780].
210 American Academy of Pediatrics Committee on Environmental Health. Screening forelevated blood lead levels. Pediatrics. 1998;101(6):1072–1078.
211 Ellis MR, Kane KY. Lightening the lead load in children. Am Fam Physician. 2000;62(3):545-554. [pmid: 10950212].
212 Centers for Medicare and Medicaid Services. Medicaid and EPSDT. Added 6.8.05; http://www.cms.hhs.gov/medicaid/epsdt/default.asp. Accessed June 5, 2005.
213 Markowitz M, Rosen JF, Clemente I. Clinician follow-up of children screened for lead poisoning. Am J Public Health. 1999;89(7):1088-1090. [pmid: 10394321].
214 Campbell JR, Schaffer SJ, Szilagyi PG, O'Connor KG, Briss P, Weitzman M. Blood lead screening practices among US pediatricians. Pediatrics. 1996;98(3 Pt 1):372-377. [pmid: 8784359].
215 New York State Department of Health and American College of Obstetricians and Gynecologists District II. Lead poisoning prevention guidelines for prenatal care providers. Albany, NY: New York City Department of Health; 1995.
216 Pirkle JL, Brody DJ, Gunter EW, et al. The decline in blood lead levels in the United States. The National Health and Nutrition Examination Surveys (NHANES). JAMA. 1994;272(4):284-291. [pmid: 8028141].
217 Annest JL, Pirkle JL, Makuc D, Neese JW, Bayse DD, Kovar MG. Chronological trend in blood lead levels between 1976 and 1980. N Engl J Med. 1983;308(23):1373-1377. [pmid: 6188954].
218 Centers for Disease Control and Prevention. Blood lead levels - United States, 1988-1991. MMWR. 1994;43:545-548. [pmid: 8035771].
219 Hayes EB, McElvaine MD, Orbach HG, Fernandez AM, Lyne S, Matte TD. Long-term trends in blood lead levels among children in Chicago: relationship to air lead levels. Pediatrics. 1994;93(2):195-200. [pmid: 8121731].
220 Davis JM, Elias RW, Grant LD. Current issues in human lead exposure and regulation of lead. Neurotoxicology. 1993;14(23):15-27. [pmid: 8247390].
221 Galal-Gorchev H. Dietary intake, levels in food and estimated intake of lead, cadmium, and mercury. Food Addit Contam. 1993;10(1):115-128. [pmid: 8504867].
222 Prpic-Majic D, Pongracic J, Hrsak J, Pizent A. A follow-up study in a lead smelter community following the introduction of an effective pollution control system. Isr J Med Sci. 1992;28(89):548-556. [pmid: 1428809].
223 Yankel AJ, von Lindern IH, Walter SD. The Silver Valley lead study: the relationship between childhood blood lead levels and environmental exposure. J Air Pollut Control Assoc. 1977;27(8):763-767. [pmid: 886085].
224 Department of Health and Human Services, Department of Housing and Urban Development, and Environmental Protection Agency. Report of the Interagency Task Force on the Prevention of Lead Poisoning: a report to Congress. Washington, DC: Department of Housing and Urban Development. 1993.