# Discussion

A summary of the evidence for each key question addressed in the evidence synthesis is provided in Table 6. There is fair evidence that screening for elevated lead levels in asymptomatic children at increased risk for lead exposure will improve clinical outcomes. Because there have been no controlled trials directly evaluating screening for elevated lead levels, this conclusion is based on a chain of evidence constructed from studies of weaker design. First, in young asymptomatic children, blood lead levels as low as 10 micro-g/dL and perhaps lower are associated with measurable neurodevelopmental dysfunction. Second, although the national prevalence of elevated lead levels has declined substantially in the past two decades, a high prevalence persists in some communities, particularly poor urban communities in the Northeast and Midwest U.S. Third, measurement of venous blood lead concentration is a reliable, precise and reasonably valid screening test for assessing lead exposure. Fourth, current interventions, including residential lead hazard control and chelation therapy, can reduce blood lead levels in children identified with levels ≥25 micro-g/dL, although the quality of evidence supporting their effectiveness is weak and a beneficial effect on IQ or other clinical outcomes has not yet been demonstrated. Well-designed randomized controlled trials do not support beneficial effects of chelation therapy for asymptomatic children with levels <45 micro-g/dL. There is also weak evidence that screening high-risk children for elevated lead levels results in improved clinical outcome compared to historical controls identified by case finding. Based on this evidence of the current burden of suffering and the effectiveness of early detection, the Task Force recommends screening children at increased risk for lead exposure.

Table 6 Summary of the Evidence

Key Question | Findings
Children
KQ 1. Is there direct evidence that screening for lead results in improved health outcomes (i.e. cognitive changes, behavioral problems, learning disorders)? | There is no direct evidence from controlled studies of screening.
KQ 2. What is the prevalence of elevated lead in children? | The prevalence of blood lead ≥10 micro-g/dL among children aged 1–5 years in the U.S. has declined from 9% in 1988-1991 to 1.6% 1999-2002.
Are there population-level risk factors that identify children at higher risk for elevated lead levels? | Population-level risk factors among children include age < 5 years; urban residence; low income; low parental educational attainment; pre-1950 housing; and recent immigration. Mean blood levels among African-American children remain significantly higher than Mexican American children and non-Hispanic whites.
KQ 3. Can screening tests accurately detect elevated blood lead levels? | Blood lead concentration is more sensitive and specific than free erythrocyte proptoporphyrin (EP) levels, but can be affected by environmental lead contamination and laboratory analytic variation. In one study of 47,230 suburban and rural children, 4.7% had an elevated EP level, while only 0.6% had elevated BLL. Capillary sampling has false-positive rates of 3–9%, and false-negative rates of 1–8%, compared with venous blood lead levels.
How accurate are questionnaires (or other tools) for risk factor assessment at various blood lead levels? | The sensitivity and specificity of questionnaires vary considerably with the prevalence of EBLL in the population surveyed and the cutoff BLL (10 vs. 15 micro-g/dL). One study found that rental status, lead-contaminated floor dust, and poor housing condition were associated with EBLL, suggesting that housing characteristics can be used to identify homes where a lead hazard may exist before or during occupancy.
What is the optimal frequency for screening? What is the optimal frequency for repeat testing? | Not addressed in this review.
KQ5: Do interventions for elevated lead levels result in improved health outcomes or lead levels? | We identified no evidence that treatment, lead abatement, or education improved neurocognitive outcome in asymptomatic children with mildly-moderately increased lead levels. In one trial of succimer there was no benefit or slight harm. Some interventions have small, inconsistent, or unsustained effects on lead levels in high-risk children.
KQ4, KQ6 What are the adverse effects of screening and treatment? | See text.
KQ7: What are cost effectiveness issues? | Not addressed in this review.
Pregnant Women
KQ 1. Is there direct evidence that screening in asymptomatic pregnant women for lead results in improved health outcomes? | There is no direct evidence from controlled studies of screening that screening improves maternal hypertension, cognitive changes in offspring or perinatal outcomes.
KQ 2. What is the prevalence of elevated lead in pregnant women? | In 1992, two large surveys of low-income pregnant women found 0% and 6% with blood levels >15 micro-g/dL. A longitudinal study of pregnant women in Boston found that umbilical cord blood levels declined 82% between 1980 and 1990.
Are there population-level risk factors that identify pregnant women at higher risk for elevated lead levels (i.e., geography, racial/ethnicity, SES, age)? | Ethnic background, country of origin, and immigrant status of birth mothers have been shown to be associated with prenatal lead exposure in newborns. Cigarette smoking, maternal age, and alcohol intake have been found to increase umbilical cord blood lead levels.
KQ 3. Can screening tests accurately detect elevated blood lead levels? | See KQ 3. in Children, above.
How accurate are questionnaires (or other tools) for risk factor assessment at various blood lead levels? | We found one study of a 4-question prenatal survey developed by the CDC that had a sensitivity of 75.7%, and a negative predictive value of 93.1%.
What is the optimal frequency for screening? What is the optimal frequency for repeat testing? | Not addressed in this review.
KQ5: Do interventions for elevated lead levels result in improved health outcomes? | We identified no evidence that treatment, lead abatement, or education improved neurocognitive outcome in asymptomatic children with mildly-moderately increased lead levels. In one trial of succimer there was no benefit or slight harm.
KQ4, KQ6 What are the adverse effects of screening and treatment? | See text.

While no studies have evaluated a specific age at which to screen, the natural history of blood lead levels in children, which increase most rapidly between 6 and 12 months and peak at age 18–24 months, suggests that screening at about 12 months of age is likely to be most effective for the early detection of elevated lead levels.

For those children who are screened and found to have initial blood lead levels <25 micro-g/dL, there is as yet little evidence regarding the effectiveness of early detection and intervention, or of repeated screening to detect further increases in blood lead. Longitudinal and cross-sectional studies suggest that in children ≥2 years, most such levels will decline naturally with time, but elevated levels may persist in children who are chronically exposed.

There is no direct evidence comparing the outcomes of universal screening with the outcomes from targeted screening for elevated lead levels. Recent studies indicate that the prevalence of elevated blood levels in the U.S. has declined dramatically in the past two decades, but local prevalence is highly variable, with more than tenfold differences between communities. In a community with a low prevalence of elevated blood lead levels, universal screening may result in disproportionate risks and costs relative to benefits. The prevalence level at which targeted screening can replace universal screening is a public health policy decision requiring consideration of factors in addition to the scientific evidence for effectiveness of early detection, such as available resources, competing public health needs, and costs and availability of alternative approaches to reducing lead exposure. Clinicians can consult with their local or state health department regarding appropriate screening policy for the local child population.

In communities where data suggest that universal screening is not indicated, there may nevertheless be some children who are at increased risk of blood lead levels in the range for which individual intervention by chelation therapy or residential lead hazard control has been demonstrated to be effective. In addition to risks from housing, these children may have had exposure to other lead sources such as lead-based hobbies or industries, traditional ethnic remedies, or lead-based pottery. Selective blood lead screening of such high-risk children is appropriate even in low prevalence communities. There is fair evidence that a validated questionnaire of known and acceptable sensitivity and specificity can identify those at high risk. In several studies, the CDC^124^ and similar questionnaires correctly identified 64% to 87% of urban and suburban children who had blood lead levels ≥10 micro-g/dL. These questionnaires have not been adequately evaluated as a screening tool to detect higher blood lead levels (e.g., ≥20–25 micro-g/dL), or to detect exposure in other populations (e.g., migrant workers, rural communities). Locale-specific questionnaires that inquire about likely local sources of lead exposure may lead to improved prediction.

As is the case in children, there are no controlled trials evaluating screening for elevated lead levels in pregnant women, nor are there sufficient data to construct an adequate chain of evidence demonstrating benefit. The prevalence of levels >15 micro-g/dL appears to be quite low in pregnant women. There is fair evidence that mildly elevated lead levels during pregnancy are associated with small increases in antepartum blood pressure, but limited evidence that these levels have important adverse effects on reproductive or other outcomes, including intelligence of offspring. An extensive literature search failed to identify studies evaluating screening or intervention for lead exposure in pregnant women. There are potentially important adverse effects of chelation therapy on the fetus and of residential lead hazard control on both the pregnant woman and fetus if they are not performed according to established standards. Removal to a lead-free environment would theoretically be effective in reducing lead exposure but has not been specifically evaluated in pregnancy. There is thus insufficient evidence to recommend for or against screening pregnant women for the detection of elevated lead levels.

Community-based interventions for the primary prevention of lead exposure are likely to be more effective, and may be more cost-effective, than office-based screening, treatment and counseling.^29^ Community, regional, and national environmental lead hazard reduction efforts, such as reducing lead in industrial emissions, gasoline, and cans, have proven highly effective in reducing population blood lead levels.^216^–^223^ Remaining important sources of lead (e.g., lead paint and pipes in older homes, lead-contaminated soil) are, however, more difficult to address on a population-wide basis. Studies of community-based efforts to reduce lead exposure from these and other sources in order to prevent the occurrence of elevated lead levels are ongoing.^23,^ ^158,^ ^224^ Evaluation of the effectiveness of community-based interventions, and recommendations regarding their use, are beyond the scope of this document.