# Results

## Key Question 1: Screening in children and asymptomatic pregnant women

There is no direct evidence from controlled studies that screening children for elevated blood lead levels results in improved health outcomes. There is no direct evidence from controlled studies that screening improves maternal hypertension, cognitive changes in offspring or perinatal outcomes.

## Key Question 2: Prevalence; Burden of Suffering

Summary: The prevalence of elevated blood lead levels among children and women in the United States, like that in the general population, continues to decline sharply, due primarily to marked reductions in lead in gasoline, air, dietary sources, and residential paint. However, the prevalence still varies substantially among different communities and populations, and children and pregnant women share many of the same risk factors for elevated blood lead. Correlates of higher blood lead levels at all ages include minority race/ethnicity; urban residence; low income; low educational attainment; older (pre-1950) housing; home renovation or remodeling; pica; use of ethnic remedies, cosmetics, and lead glazed pottery; occupational and para-occupational exposures; and recent immigration. Alcohol use, smoking, pica, and immigration status have been demonstrated as risk factors among pregnant women.

Recent observational studies have demonstrated an inverse relationship between historical blood lead levels in children and subsequent measures of behavioral and cognitive performance at blood lead levels of <10 micro-g/dL. Recent observational studies provide limited, preliminary data that prenatal blood lead levels <10 micro-g/dL may be associated with neurodevelopmental delay or impairment. Study design and measurement issues, however, limit interpretation of these studies. Studies also suggest that levels of maternal exposure in this range may be associated with increased risk for spontaneous abortion, hypertension in pregnancy, and adverse effects on fetal growth^4^.

### What is the prevalence of elevated lead in children?

The prevalence of elevated blood lead levels in the U.S. population continues to decline sharply, due primarily to marked reductions in lead in gasoline, air, dietary sources, and residential paint.^5^ In a 1999-2002 national survey of children aged 1–5 years, 1.6% had blood lead levels ≥10 micro-g/dL, compared to 9% in a similar survey in 1988-1991.^6^ (The units micrograms/deciliter (micro-g/dL) will be used throughout this chapter: to convert to micro-mol/L, divide by 20.72.) Although the prevalence of elevated blood lead levels among children ages 1–5 years declined by 64% from 1991-94 through 1999-2002, the prevalence still varies substantially among different communities and populations, and an estimated 310,000 children remain at risk for exposure to harmful levels of lead.^5^

### What is the prevalence of elevated lead in asymptomatic pregnant women?

Blood lead levels and blood umbilical cord lead levels are frequently used to assess both the mother's and fetus' levels of lead exposure and risk. In 1992, two large surveys of low-income pregnant women found 0%^7^ and 6%^8^ with blood lead levels >5 micro-g/dL. A study of all women who enrolled in prenatal clinics in Mahoning County, Ohio, from 1990 to 1992 found that 13% of prenatal patients had blood lead levels ≥10 micro-g/dL, with 1% having blood lead levels greater than 15 micro-g/dL.^9^ Population mean blood lead levels in women of childbearing age and pregnant women have fallen over the past two decades. Although it was estimated in 1990 that 4.4 million women of childbearing age, and over 400,000 pregnant women, had blood lead levels of >10 micro-g/dl,^10^ a recent study of 1109 infants in Quebec, Canada, found a mean cord blood lead of 1.5 micro-g/dL (0.076 umol/l; 95% CI = 0.074, 0.079).^11^ In a recent review of NHANES data of 4,394 women of child-bearing age, the GM blood lead levels 1.78 micro-g/dL^12^ and a longitudinal study of pregnant women in Boston demonstrated that umbilical cord blood lead levels declined 82% between 1980 and 1990.^13^

### Are there population-level risk factors that identify children at higher risk for elevated lead levels (i.e., geography, race/ethnicity, socioeconomic status, age)?

The highest geometric mean blood lead levels (GM blood lead levels) in the U.S. occur in children aged 1–5 years (GM 1.9 micro-g/dL) and in adults ≥60 years of age (GM 2.2 micro-g/dL), with the lowest in youth aged 6–19 years (GM 1.1 micro-g/dL).^5^ Children under 5 years of age are at greater risk for elevated blood lead levels and lead toxicity because of increased hand-to-mouth activity, increased lead absorption from the gastrointestinal tract, and the greater vulnerability of a developing central nervous system.^14^ Geometric mean levels are significantly higher in males than in females except among children aged 1–5 years.^5^

Correlates of higher blood lead levels at all ages include minority race/ethnicity, urban residence, low income, low educational attainment, older (pre-1950) housing, and recent immigration.^5,^ ^15^–^19^ These factors are associated with increased exposure to important lead sources, including dilapidated housing with lead-based paint, lead-soldered pipes and household lead dust, and lead in dust and soil from heavy traffic and industry.^20^–^25^ There have been major reductions in the number of U.S. homes with lead-based paint from the estimated 64 million in 1990, but approximately 24 million housing units still contain substantial lead hazards, with 1.2 million of these units occupied by low-income families with young children.^5,^ ^26^

Other potential sources of household lead exposure include clothing or waste material brought home by workers in lead-using industries or hobbies, lead-based paint and dust contamination in pre-1978 housing undergoing remodeling or renovation, ^19^ dietary intake from lead-contaminated consumer products, drinking water, and lead-based pottery, and traditional ethnic remedies.^5,^ ^27^–^30^

Geometric mean blood lead levels among African-American children (2.8 micro-g/dL) remain significantly higher than Mexican American children (1.9 micro-g/dL) and non-Hispanic whites (1.8 micro-g/dL). Even among low income families, however, GM blood lead levels declined significantly from 1991-1994 (3.7 micro-g/dL) to 1999-2002 (2.5 micro-g/dL).^5^

### Are there population-level risk factors that identify pregnant women at higher risk for elevated lead levels?

A woman of childbearing age with a high blood lead level risks transmitting a high blood lead level to her unborn child.^31^ Ethnic background, country of origin, and immigrant status of birth mothers, as well as lifestyle, age, and work patterns of pregnant women have shown to be associated with prenatal lead exposure in newborns. Multivariate analyses of pregnant women in Quebec, Canada, revealed that both cigarette smoking (15% increase) and alcohol intake (17% increase) make significant and independent contributions to cord blood lead concentrations.^32^ In a survey of 10 Quebec hospitals, umbilical cord blood samples were obtained from 1,109 newborns. Although blood lead levels were considered low, a statistically significant relationship was observed between maternal age, and smoking during pregnancy, in cord blood lead concentrations.^11^

One hundred fifty-nine mother-infant pairs from a cohort of women receiving prenatal care in Pittsburgh, Pennsylvania, provided blood samples at delivery for lead determination. Alcohol use was associated with relatively greater cord blood lead compared with maternal blood lead. No association was found with cord blood lead or maternal blood lead with smoking, physical exertion, or calcium consumption.^33^

A recent study in New York City of pregnant women in their third trimester with an incident blood lead level of 20 micro-g/dL or greater showed they had newborns with a median incident blood lead level of 12 micro-g/dL. In addition, maternal blood lead levels were directly associated with gestational age and pica behavior. These cases were more than twice as likely to be foreign-born women.^34^ Maternal immigrant status and pica behavior are also associated with high infant blood lead level.

### Neurotoxic effects of lead exposure in children

Very high levels of inorganic lead exposure can produce serious neurological complications, which may result in death or long-term sequelae.^21,^ ^35,^ ^36^ A number of adequately designed and conducted prospective cohort studies from a broad range of child populations have reported that a rise in blood lead from 10 to 20 micro-g/dL is associated with a likely decrement of 2–3 points (reported range -6 to +1) in intelligence test scores (IQ).^37^–^43^ The variety of test instruments that have been used, and differences in adjustment for important covariates, make direct comparison of these studies difficult, but a consistent negative effect on intellectual development is reported.

In these studies, the mean blood lead levels at age 1–2 years (7.7–35.4 micro-g/dL) were higher than the current U.S. mean for this age group, but most levels were below 35 micro-g/dL. A meta-analysis^44^ that included the five oldest of these cohort studies concluded that a doubling of blood lead levels from 10 to 20 micro-g/dL measured at age 2 years was associated with a statistically significant mean reduction of 1–2 IQ points; evidence was inconclusive regarding an association of IQ with mean postnatal blood lead levels. Significant associations have been demonstrated between umbilical blood lead levels and neurodevelopmental testing at 2 years of age, although the association was not significant at later ages. Blood lead levels at 2 years of age, however, were associated with neurocognitive performance at 10 years of age.^14^ A recent analysis of school-aged children demonstrated a stronger cross-sectional inverse association of IQ with contemporary blood lead levels (mean BLL = 8 micro-g/dL at age 7 years) than with baseline blood levels (mean BLL = 26 micro-g/dL at 24 months old), suggesting an ongoing adverse effect of lead on cognitive performance among school-aged children.^45^

Although most cross-sectional studies evaluating the association of tooth and blood lead with IQ display methodological weaknesses such as selection bias and limited adjustment for covariates, they have been generally consistent in reporting small negative effects of elevated lead levels on IQ.^44,^ ^46^ A meta-analysis that included studies of whole tooth lead published since 1979 reported a statistically significant 1-point reduction in IQ associated with a doubling of tooth lead from 5 to 10 micro-g/g.^44^

Cross-sectional studies^47^–^51^ have consistently reported small, inverse associations between blood or tooth lead and reaction (attentional) performance, but studies evaluating the effect of mildly elevated lead levels on other measures of neurodevelopmental function (e.g., behavior, learning disorders, auditory function) have produced inconclusive results. These have been less thoroughly evaluated than IQ, however, and more recent studies suggest associations between childhood lead exposure and disorders of attention and learning, and aggressive and delinquent behavior.^14,^ ^35,^ ^52,^ ^53^

In most studies, the size of the estimates of lead effects on IQ are reduced when adjusted for potentially confounding variables,^44^ suggesting that some of the observed association may be due to imperfectly measured or unmeasured covariates. Studies in rodents and primates, however, which can avoid most of the methodological weaknesses of observational studies in humans, report cognitive, attentional, and behavioral deficits, as well as auditory and visual dysfunction, with mildly elevated blood lead levels,^54^–^56^ supporting a causal relationship between low-level lead exposure and neurotoxic effects in children.

A growing number of human epidemiology studies have reported associations between neurotoxic effects and blood lead levels once thought to be harmless. Several recent studies have demonstrated an inverse relationship between historical blood lead levels and subsequent measures of intellectual and cognitive performance at blood lead levels of <10 micro-g/dL. The shape of the dose-response curve at levels below 10 micro-g/dL is uncertain although data suggests that lead associated cognitive changes may be greater with incremental changes in blood lead levels in this range.^14,^ ^35,^ ^53,^ ^57^–^60^ A recent meta-analysis of seven prospective international cohort studies found evidence of deficits on standard IQ testing among children with maximal blood lead levels <7.5 micro-g/dL. A decline of 6.2 IQ points (95% CI, 3.8–8.6) was observed as blood lead levels increased from 1 to 10 micro-g/dL.^61^

Lead-associated effects on neurobehavioral functioning must be considered relative to other important covariates such as socioeconomic status, home and parenting environment, and genetic factors.^57^ The contribution of childhood lead exposure to the observed variance in cognitive ability (IQ testing) is believed to be in the range of 1–4%, while social and caregiving factors may be responsible for 40% or more.^52,^ ^57^ Blood lead levels, however, represent a larger proportion of the known, modifiable variance in children's cognitive ability.

### Adverse effects of lead exposure on pregnancy outcomes

The effects of very high blood lead levels during pregnancy on reproductive outcomes such as abortion and stillbirth have been recognized for many years.^21^ Observational studies in pregnant women with blood lead levels <30 micro-g/dL have reported associations between elevated levels and birth weight, length of gestation (including preterm delivery), and neonatal head circumference.^62^–^69^ The associations have been small, variable in direction of effect, and not statistically significant in most studies. These studies failed to detect important effects on other reproductive outcomes. Inconsistent results may be due in part to imprecise measures of fetal lead exposure.^68^–^72^ All but one^42^ of six previously cited cohort studies,^37^–^42^ as well as the meta-analysis described above,^44^ reported no association between antenatal or perinatal maternal blood lead levels and full-scale IQ measured at preschool or school age. Although very high lead levels in pregnancy are clearly hazardous, the adverse effects on the fetus of antepartum lead levels in the range typically found in the U.S. are not established.

### Reproductive effects

A recent review summarizing the epidemiological literature on typical community lead exposure levels, other than those associated with high occupational hazards, states that prenatal lead exposure is unlikely to increase the risk of premature membrane rupture but does appear to increase the risk of preterm delivery. This review goes on to stay that is it unclear whether prenatal lead exposure decreases infant gestational age and that increased exposure appears to be associated with reduced birth weight, but that results vary in relation to study design and degree of control for confounding. Adjustment for gestational age, a possible confounder of the birth weight-lead exposure association, did not yield clearer results.^73^

The Mexico City Prospective Lead Study examined the association of maternal prenatal blood lead level during pregnancy (range 7.5–9.0 micro-g/dl [0.36–0.43 -micro-mol/l]) and child postnatal blood lead level (range of median blood lead level from birth to 48 months 7.0–10.0 micro-g/dl [0.34–0.48 micro-mol/l]) with head circumference, in a sample of Latino immigrants living in Los Angeles. Multiple regression modeling showed significant negative associations (p<0.05, two-tailed) between 6-month head circumference and 36-week maternal blood lead level, and 36-month head circumference and 12-month blood lead level; however, these were the only significant associations among the over fifty assessed in this study.^74^

In 272 mother-infant pairs, tibia bone lead was the only lead biomarker clearly related to birth weight (other significant birth weight predictors included maternal nutritional status, parity, education, gestational age, and smoking during pregnancy). Findings suggest that bone lead might be a better biomarker of lead body burden than blood lead.^75^

### Neurodevelopmental and cognitive measures and lead effects

Recent observational studies (prospective cohort and cross-sectional) provide limited, preliminary data that prenatal blood lead levels may be associated with neurodevelopmental delay or impairment. Study design and measurement issues, however, limit interpretation of these studies.

A prospective study of 103 African American neonates with low-level parental lead exposure included a battery of 16 neonatal behavioral assessments at 1 to 2 days after birth. No differences were found in 15 of the 16 domains studied, with neonates in the higher exposure group receiving lower scores on the hand-to-mouth motor activity than did those infants in the lower exposure group (P< 0.05).^76^ A sample of 79 African-American infants with low-level prenatal parent lead exposure were given the Fagan Test of Infant Intelligence (FTII) battery at 7 months of age.^77^ Excluding all but infants with scores in the 5th and 95th percentiles of the FTII (n=5 in both groups) revealed that subjects rated at high risk for impairment on the FTII (those in the lowest 5th percentile) were 6 times more likely to be in the highest maternal blood lead level quartile (P< .004). Infants scoring in the lower 15^th^ percentile (n=12), were 2 times more likely to be in the high maternal blood lead level quartile, though significance dropped to P<0.056.^77^ The difference between the mean blood lead levels in the infants with lowest and highest FTII scores (5th and 95th percentiles) was very small, however (0.44 vs. 0.94 micro-g/dL). Recent evidence suggests that children may demonstrate differences in evoked visual and auditory potentials associated with increased levels of prenatal lead exposure.^78,^ ^79^

### Other adverse effects of lead exposure

Lead exposure affects many organ systems, including cardiovascular, renal, and hepatic, but most clinically apparent (i.e., symptomatic) effects occur with blood lead levels ≥50 micro-g/dL.^21,^ ^80^–^83^ Subclinical effects on renal function can be observed at lower levels of exposure and children may be more vulnerable.^84,^ ^85^ Small increases in systolic blood pressure have been associated with mildly elevated blood lead levels (i.e., 1–3 mmHg for a rise in blood lead from 10 to 20 micro-g/dL) in most large, population-based, cross-sectional studies evaluating nonpregnant adults and pregnant women.^86^–^92^ In children, evidence of blood pressure effects is more limited: one cross sectional study found no association between elevated blood lead levels (range 7–70 micro-g/dL) and elevated blood pressure.^93^ Adverse effects on height from lead levels well below 40 micro-g/dL have been suggested by analyses of national cross-sectional data,^94,^ ^95^ but cohort studies with more extensive covariate adjustment report either transient or no effect of elevated lead levels (peak sample means 11–17 micro-g/dL) on growth.^43,^ ^96,^ ^97^

In a cohort of women in their third trimester, immigrant women were more likely to have elevated blood lead levels and elevated blood pressure, compared to non-immigrant women. An association between elevated blood level and blood pressure was significant only in the immigrant group.^98^ Past lead exposure was associated with hypertension and elevated blood pressure during pregnancy. Bone lead concentration, however, was not shown to be related to hypertension or elevated blood lead in pregnancy.^99^

Among 110 women in their third trimester, gestational hypertension cases showed significantly higher blood lead levels than normotensives, and blood lead was significantly related to blood pressure, even after correcting for body mass indices and age. The lead:ionized calcium ratio showed a stronger association with blood pressure than lead alone.^100^ A cross-sectional study of 39 pregnant women in the third trimester of pregnancy compared red blood cell (RBC) levels of lead (Pb) and blood pressure. The study population included 20 women with normal pregnancies, 15 with mild hypertension, and 4 with severe hypertension and preeclampsia. Preeclamptic pregnancies were more likely to have an elevated RBC Pb. Rank correlation showed a significant effect of RBC Pb level on blood pressure.^101^

## Key Question 3: Accuracy of Screening Tests

### Can screening tests accurately detect elevated blood lead levels?

Screening tests considered for detecting lead exposure include blood lead and free erythrocyte (or zinc) protoporphyrin levels. Blood lead concentration is the more sensitive of the two for detecting modest lead exposure, but its accuracy, precision and reliability can be affected by environmental lead contamination during blood collection, day-to-day biologic variability, and laboratory analytic variation. Lead contamination of collecting equipment and skin contamination during capillary sampling may each positively bias blood lead levels by up to 1.0 micro-g/dL, on average, although individual effects of skin contamination may be much greater.^102^–^106^ Studies defining abnormal results as blood lead levels above 10 or 20 micro-g/dL have reported false-positive rates of 3–9% for capillary sampling, compared to simultaneously collected venous blood lead.^103,^ ^104^ Day-to-day biologic variability and trends over time contribute to higher false-positive rates for initial capillary samples when compared to results from venous testing done at a later date.^103,^ ^107^ False-negative rates with capillary sampling appear to be lower, reported in one study as 1–8% compared to venous blood.^104^ In published surveys,^102,^ ^108^ about 80–90% of clinical laboratories participating in proficiency testing programs met performance criteria for blood lead (within +/-4 micro-g/dL of target values, for values <40 micro-g/dL,^108^ unpublished national data show >95% of participating laboratories meeting these criteria and >80% achieving accuracy to within +/-2 micro-g/dL of target values (unpublished data, Centers for Disease Control and Prevention, November 1993). Nonparticipating laboratories are likely to be less proficient. Reported blood lead values may differ by as much as 5 micro-g/dL from true values due to these sources of variability and bias, and these divergences may affect the predictive value of a positive test. Results from capillary samples may vary even more, although recent studies suggest that the positive bias can be reduced with increased attention to reducing skin lead contamination.^103,^ ^104^

The erythrocyte protoporphyrin (EP) test, an indirect measure of lead exposure based on lead's effects on the hematopoietic system, is unaffected by contamination with environmental lead and is easily performed on capillary blood specimens, making it more acceptable for use with young patients. Erythrocyte (or zinc) protoporphyrin is insensitive, however, to modest elevations in blood lead levels.^8,^ ^109^–^115^ The test also lacks specificity,^8,^ ^109,^ ^110,^ ^112,^ ^113,^ ^116^ thus limiting its predictive value. In one study, EP measurements were taken on 47,230 suburban and rural children, and although 4.7% of the children had an elevated erythrocyte protoporphyrin level, only 0.6% had elevated blood lead levels.^117^

### What is the accuracy of using questionnaires (or other tools) for risk factor assessment at various blood lead levels?

In communities where there is a low prevalence of lead levels requiring individual intervention with chelation or residential lead hazard control, blood lead screening will have a low yield with many unaffected children undergoing testing at potentially high cost and inconvenience. Cross-sectional studies^118^–^123^ in urban and suburban, mostly Midwestern, populations have shown that one or more positive responses to five questions (about exposures to deteriorated paint from older or renovated housing, to other lead-poisoned children, or to lead-related hobbies or industry)^124^ detects 64–87% of children with blood lead levels >=10 micro-g/dL. Three studies reported higher sensitivities (81–100%) for blood lead levels >=15–20 micro-g/dL.^120,^ ^121,^ ^123^ None of these studies evaluated the ability of questionnaires to detect levels above 20 micro-g/dL, in part because so few patients had levels so high. Specificity among the studies ranged from 32% to 75%. In the samples with a lower prevalence (2–7%) of levels >=10 micro-g/dL, the proportion of individuals with a negative questionnaire who had elevated blood lead levels was predictably low (0.2–3.5%), but increased to 19% when the population prevalence of elevated lead levels was higher (17–28%).

More recent studies of the utility of questionnaires to assess the risk of lead exposure in children in both urban and rural settings have demonstrated a low prevalence of elevated blood lead levels and poor sensitivity and specificity.^125^–^128^ Studies of questionnaires modified for local use provide some evidence of clinical utility for identifying children with elevated blood lead levels,^128,^ ^129^ compared to the standard CDC questionnaire.

Other studies have reported high false-positive rates for questionnaires^126,^ ^128^ and that resource considerations^125^ are important when formulating a screening program. A population-based follow-up study (n=31904) showed that raising the action level for screening to 15 micro-g/dL in this sample would have eliminated the unnecessary follow-up of 5,162 children, 3,360 of whom were falsely identified as having elevated lead levels.^130^

A recent study identified housing risk factors associated with elevated blood lead levels (≥10 micro-g/dL) among 481 children residing in Rochester, New York. Housing characteristics including rental status, lead-contaminated floor dust, and poor housing condition were all associated with EBLL (sensitivity 47–92%, specificity 28–76%, positive predictive value 25–34%, negative predictive value 85–93%), suggesting that housing characteristics and floor dust lead levels can be used to identify homes where a lead hazard may exist before or during occupancy.^131^

### Prenatal screening with questionnaires

A maternal survey using four questions recommended by the CDC was evaluated in a study of 314 new prenatal patients. In this sample, the prevalence of elevated maternal lead levels (at or greater than 10 micrograms/dL or 0.483 mumol/L) was 13%. Subjects with a positive response to at least one question were more likely to have elevated blood lead than those who answered negatively to all four questions (relative risk = 2.39, 95% confidence interval 1.17–4.89; P = .01). The CDC questionnaire had a sensitivity of 75.7%. Among women who answered “no” to all 4 questions, the probability of having an elevated lead level was reduced from 13% to 6.9% (negative predictive value of 93.1%). The most predictive single item was ‘home built before 1960.’ The study also identified a high prevalence of elevated blood lead among children living with women with elevated blood lead levels.^9^

## Key Questions 5: Effectiveness of Early Detection

Detection of lead exposure before the development of potentially irreversible complications permits the clinician to recommend environmental interventions to limit further exposure and, when necessary, to begin medical treatment with chelating agents. Early detection may also result in interventions that prevent exposure of other children to lead (the child with elevated blood lead level acting as a sentinel for a hazardous environment). There is relatively little convincing evidence that these interventions improve health, however. One issue is that most available studies in asymptomatic children evaluate the effects of various interventions on blood lead levels rather than on clinical outcomes. Second, blood lead levels in childhood, after peaking at about 2 years of age, decrease even without intervention.^6^ Longitudinal studies of asymptomatic children with elevated lead levels show reductions in blood lead levels during short- and long-term follow-up in the absence of any intervention,^132,^ ^133^ a result attributable at least in part to regression to the mean, random variation, laboratory error, and redistribution from blood to other tissues. To evaluate adequately the effects of interventions on blood lead levels, studies must take into account these changes over time, preferably by the use of controls, individuals who do not receive the intervention.

### Effect of screening on clinical outcomes

Evidence is not available to demonstrate that universal screening for blood lead results in better clinical outcomes than either screening targeted to high-risk persons or individualized testing in response to clinical suspicion. Several older studies reported that, compared to historical results from individualized testing, intensive screening programs targeted to children in high-risk neighborhoods reduced case fatality rates, mortality rates, and proportions of children detected with very high blood lead levels or who developed symptomatic lead poisoning.^134^–^136^ In the absence of concurrent controls, it is not clear whether the reported reductions in mortality and case fatality rates were due to screening or to improvements in medical care over time. Reductions in mean lead levels may also have been due to secular trends, changes in screening tests, and to screening greater numbers of children, including many at low risk for severe lead poisoning. Thus, the available evidence regarding the efficacy of screening programs is weak.

### Do interventions for elevated lead levels result in improved health outcomes?

There is substantial evidence that chelating agents benefit children with symptomatic lead poisoning, but no studies have demonstrated clinical benefits of chelation therapy in asymptomatic children. A large multicenter randomized controlled trial sponsored by the U.S. National Institute for Environmental Health Science (NIEHS) enrolled children in 1994-1997 to assess the effect of oral chelation therapy with succimer on IQ in young children with venous blood lead concentrations of 20–45 micro-g/dL.^137^ Follow-up testing at 36 months demonstrated a mean IQ one point lower and a lower parental rating of behavior among the succimer group compared to placebo. Although succimer-treated children did slightly better on a test of learning ability, none of the differences between the groups were statistically significant.^138^ Reanalysis of the same data using the change in blood lead level as the independent variable demonstrated a 4.0 point improvement in cognitive scores for every 10 micro-g/dL reduction in blood lead level, but only in the placebo group, suggesting that factors other than declining blood lead contributed to cognitive improvement, or that treatment had an adverse effect on cognitive performance.^139^ Assessment of neurobehavioral outcomes at 7 years of age revealed no statistically significant differences on a battery of neurobehavioral tests, except that the succimer group had worse attention-executive function scores.^140^ Treatment also appeared to have an adverse effect on mean height.^141^ The Trial Group concluded that chelation therapy was not indicated for children with blood lead levels <45 micro-g/dL.^138,^ ^140^

An observational study^142,^ ^143^ compared children with blood lead levels between 13 and 46 micro-g/dL (median 30 micro-g/dL), who did and did not receive EDTA chelation therapy depending on the results of a lead mobilization test. There was no effect of chelation on IQ at either 7 weeks or 6 months follow-up after controlling for age and initial IQ. Changes in concentrations of blood lead, bone lead, and EP also did not differ significantly between chelated and unchelated children. The greatest reductions in blood lead were associated with the highest initial lead levels, independent of chelation. The method of treatment assignment (i.e., based on a positive mobilization test) was most likely to have biased the study toward finding an effect of chelation, yet no effect was observed. Despite evidence of efficacy in lowering blood lead on a short term basis, there is little evidence presently available to confirm a clinical benefit from chelation therapy for children with lead levels <45 micro-g/dL. Ethical considerations preclude such trials for children with blood lead levels above 45 micro-g/dL.

We found no studies evaluating clinical outcomes after residential lead hazard control.

### Effects of chelation therapy on blood lead levels

In the previously cited NIEHS-sponsored RCT of oral chelation in young children with venous blood lead concentrations of 20–45 micro-g/dL (TLC Study), which reported no effects of chelation on IQ (Table 1),^137^–^140,^ ^144^ blood lead levels fell steeply in the treatment group in the first week (mean 11 micro-g/dL lower) but then began to rebound. Blood lead levels also dropped in the placebo group, but more slowly. Blood lead levels were 77% of baseline in the succimer group (88% of baseline among placebo) at seven weeks after initiation of therapy. Mean blood lead levels among the treatment group were 4.5 micro-g/dL and 2.7 micro-g/dL, at six and twelve months respectively, but by 24 months the difference between treatment and placebo groups was not significant.^144^

Table 1 Effects of Chelation on Children's Blood Lead Levels

Author, Year | Aims | Study Design | Type of Intervention | N | Setting | Population/ Risk Factors | Source of Exposure/ Risk Factors | Lead Levels | Main Eligibility Criteria | Duration of Follow-up | Interventions Described | Outcomes Assessed | Results | Adverse Effects (NR for absence; ND for failure to describe) | Comments | Quality Rating
Besunder, 1995^150^ | To determine the short-term efficacy of DMSA in mild to moderate lead intoxication | Retrospective case-series | Chelation with DMSA and abatement of domestic lead hazards | 46 treated, 18 excluded, N = 28 | Regional referral lead treatment program, urban hospital, Cleveland OH | Referral population, 35% | Housing | 25–49 ug/dl | Convenience sample. Children receiving 19 days of DMSA treatment during 6/91 to 5/93, with initial blood lead level between 25 and 49 ug/dl. Exclusion criteria: drug cosponsored trial (N=14), prior (previous 28 days) chelation therapy, concommitant chelating agent (EDTA, N=3), documented noncompliance (N=1). | 80 days | DMSA 10 mg/kg every 8 hours for 5 days, followed by 10 mg/kg every 12 hours for 14 days | Blood lead level, ZPP | Blood lead level: post-treatment (day 18) -43% (± 20.8%), 80 Days -31% (± 20.2%); ZPP post-treatment (day 18) -12% (±21.7%), 80 days -32% (±21.9%) | Neutropenia (N=1) | No control group, cannot exclude other intervention (abatement of domestic lead hazards prior to treatment) | Case series; non-controlled study.
| | | | | | African American, 10%
| | | | | | Hispanic
Chisolm, 2000^152^ | Assess safety and efficacy of DMSA | Open label non-comparative (case-series) | Chelation with DMSA, relocation to lead-safe housing | 59 | Regional lead treatment referral center, Baltimore, MD | Children ages 12–65 months | Housing | 25–70 ug/dl | Convenience sample. Children 12–72 months old (actual range 12–65 months), with initial blood lead level 25–120 ug/dl (actual range 25–70 ug/dl), residing in lead-safe housing for duration of study, asymptomatic, having no other disease or other lead treatment in 2 prior months | 21 days | 1050 mg/ m⁁2/day DMSA in three divided doses for five days, followed by 700 mg/ m⁁2/ day in two dived doses for 21–23 days | Blood lead level | Mean blood lead level decreased to below 35% of pretreatment value after 4 weeks of DMSA treatment, and rebounded to 58% of pre-treatment level 2–3 weeks after cessation of therapy | Elevated alkaline phosphate levels (n=2), eosinophilia (N=1) | | Case series; non-controlled study.
Dietrich, 2004^140^ | To assess neurobehavioral outcomes of children in the TLC study at 7 years of age. | Randomized multicenter, placebo controlled, double-blind trial | Chelation with DMSA after domestic cleaning with HEPA vacuum and damp cloth wiping | 1854 evaluated, 780 randomized | Multicenter trial (Baltimore, Cincinnati, Columbus, Newark, and Philadelphia) | Children ages 12–33 months, 77% African-American. Most had poor, single mothers and lived in older, poorly maintained residences. | Housing | 20–44 ug/dl | Children ages 12–33 months with blood lead level 20–44 ug/dl on two occasions, living in a residence suitable for lead dust reduction. Recruitment varied by location. Patients were randomized by strata to treatment or placebo. | 6 years (until 7 years of age) | DMSA treatment lasting 26 days, dose based on body surface area; treatment repeated up to 3 times for persistently elevated blood lead level. Domestic cleaning with HEPA vacuum and damp cloth wiping | Cognition, behavior, learning and memory, attention, neurmotor—a battery of tests | No statistically significant difference in neurobehavioral outcomes except DMSA-treated children did worse on attention/executive functions | No statistically significant difference compared to placebo. Excess noted: trauma, scalp rashes, neutropenia/thrombocytopenia, elevated ALT. | High quality | Good
Liebelt, 1994^148^ | To compare effect of DMSA treatment in children with initial blood lead level< 45 ug and > 45 ug | Retrospective cohort study | Chelation with DMSA | 30 | Regional referral lead treatment program in urban children's hospital, Boston, MA | Ages 5–161 months (mean 34 months) | Housing | Range=20–60 ug/dl. GP1 (N=23) < 45 ug (mean = 31 ug), GP2 (N=7) > 45 ug (mean=51 ug) | 30 consecutive children (convenience sample) who received DMSA during a 15 month period. Indications for DMSA use: 11 = blood lead level > 45 ug/dl, 11 =complications resulting from use of pencillamine (another chelator), 1=chronic renal failure thought to preclude penicillamine use, 7 = failure of penicillamine and EDTA (persistent elevated blood lead level) | 6 months | DMSA 30 mg/kg daily divided into 3 doses for five days, followed by 20 mg/kg daily in two divided doses for 14 days | Blood lead level, ZPP, AST, ALT | GP1 (<45 ug): mean blood lead level declined to 60% (19ug/dl) of pretreatment level during treatment, and rebounded (22 days after termination of treatment) to 74% of pretreatment levels, a net 26% reduction in mean blood lead level; GP2 (>45ug): mean blood lead level declined to 58% (30 ug/dl) during treatment, and rebounded (18 days after termination of treatment) to 69% of pretreatment level, a net 31% decrease in mean blood lead level. | Vomitting/diarrhea (N=1), mildly but statistically significantly increased ALT levels (mean 26 ± 3 mU/ml) (N=17) | No statistically significant difference in mean blood lead level percentage decrease between groups. Similar percentage reduction in both groups. Absolute reduction of blood lead level greater in high blood lead level group. | Case series; non-controlled study.
Liu, 2002^139^ | A reanalysis of TLC data using change in blood lead level as independent variable (TLC trial) | Randomized multicenter, placebo controlled, double-blind trial | Chelation with DMSA after domestic cleaning with HEPA vacuum and damp cloth wiping | 1854 evaluated, 780 randomized, results from 741 reanalyzed for this study | Multicenter trial (Baltimore, Cincinnati, Columbus, Newark, and Philadelphia) | Children ages 12–33 months, 77% African-American. Most had poor, single mothers and lived in older, poorly maintained residences. | Housing | 20–44 ug/dl | Children ages 12–33 months with blood lead level 20–44 ug/dl on two occasions, living in a residence suitable for lead dust reduction. Recruitment varied by location. Patients were randomized by strata to treatment or placebo. | 36 months | DMSA treatment lasting 26 days, dose based on body surface area; treatment repeated up to 3 times for persistently elevated blood lead level. Domestic cleaning with HEPA vacuum and damp cloth wiping | Change in cognitive function by change in blood lead level | Six months after treatment, blood lead level had fallen a similar amount in both DMSA and placebo groups. There was no association between change in blood lead level and change in cognitive test score. blood lead level continued to fall, but at 36 months after treatment, cognitive test scores improved 4.0 points for every 10 ug/dl drop in blood lead level in the placebo group only. This implies that factors other than declining blood lead levels per se are responsible for the cognitive improvement. The data do not support the hypothesis that lead-induced cognitive defects are reversible by chelation therapy. | No statistically significant difference compared to placebo. Excess noted: trauma, scalp rashes, neutropenia/thrombocytopenia, elevated ALT. | Suggests that chelation may have adverse effect on cognitive development. | Good
Markowitz, 1996^157^ | To determine the pattern of change in blood Pb (BPb) levels in the absence of chelation therapy | non-compatible study, cross sectional | observation, education | 79 (206 eligible, 113 enrolled, 79 completed | regional referral clinic NYC, NY | Low income, inner city, 2/3 Hispanic 1/3 African American | Housing | 25–55 ug/dl | Ages 1–7, blood lead level 25–55 ug, negative EDTA mobilization test, no prior chelation therapy, no neurobehavioral disorders from other causes | 6 months | Eligible children received the following interventions: notification of the health department to remediate lead hazards; reinforced educational efforts about the toxicity sources and treatment of Pb during 10 clinic and 3 home visits; and iron therapy for children with ferritin levels less than 16 g/l. To quantify the lead paint hazards in the home, we combined a visual rating of the surfaces (intact to peeling) with an X-ray fluorescence (XRF) measurement of the lead content of the painted surface. The sum of these assessments is termed the home environmental score (HES). | Blood lead level | blood lead level declined 27% on average over 6 months. In 2/3, blood lead level declined to < 25 ug/dl, in 7% blood lead level declined to <15 ug/dl | ND | Mixed intervention. Describes home assesment tool (HES: home environmental score) | Case series; non-controlled study.
O'Connor, 1999^151^ | To determine the effectiveness of DMSA and environmental modification vs. placebo and environmental modification | Randomized placebo-controlled double-blind trial | Chelation with DMSA, domestic cleaning and repair | 39 | Urban children's hospital, Cleveland, OH | Low-income African-American inner city children 2.5–5 years old | Housing | 30–45 ug/dl | Recruited from urban children's hospital, pediatric clinic or from referral practice of author. Exclusion criteria: previously high blood lead level (> 45 ug/dl) with chelation or history of numerous missed scheduled appointments or difficulty contacting family. | 6 months | Children weighing < 15 kg: 1000 mg DMSA t.i.d. for 5 days followed by 100 mg bid for 14 days; Children weighing > 15 kg: 200 mg tid for 5 days, followed by 200 mg bid for 14 days | Blood lead level | DMSA group: Baseline 34.9 ± 4.7 ug/dl, 1 month 27.4 ± 7.5 ug/dl, 6 months 28.8 ± 6.4 ug/dl; Placebo baseline 33.0 ± 6.2 ug/dl, 1 month 33.2 ± 10.3 ug/dl, 6 months 25.1 ± 6.8 ug/dl (p=0.06). | ND | | Fair
| | | | | | | | | | | | | Differences in blood lead level between groups were not statistically significant (p = 0.16 at 1 month, p = 0.06 at 6 months)
Peterson, 2004^141^ | To determine if chelation would have beneficial effect on growth in lead-exposed children (TLC trial) | Randomized multicenter, placebo controlled, double-blind trial | Chelation with DMSA after domestic cleaning with HEPA vacuum and damp cloth wiping | 1854 evaluated, 780 randomized | Multicenter trial (Baltimore, Cincinnati, Columbus, Newark, and Philadelphia) | Children ages 12–33 months, 77% African-American. Most had poor, single mothers and lived in older, poorly maintained residences. | Housing | 20–44 ug/dl | Children ages 12–33 months with blood lead level 20–44 ug/dl on two occasions, living in a residence suitable for lead dust reduction. Recruitment varied by location. Patients were randomized by strata to treatment or placebo. | 34 months | DMSA treatment lasting 26 days, dose based on body surface area; treatment repeated up to 3 times for persistently elevated blood lead level. Domestic cleaning with HEPA vacuum and damp cloth wiping | Change in height and weight from baseline to 9 month follow up and from b | Difference in mean change in height between DMSA treatment vs Placebo. 0–9 months: -0.27 cm (CI = -.42, -.11), 0–34 months -0.43 cm (CI -0.77, -0-.01). | Small, marginally significant decrease in height among treatment group compared to placebo. Excess noted: trauma, scalp rashes, neutropenia/thrombocytopenia, elevated ALT. | Chelation may have adverse effect on growth | Good
Rogan, 1998^137^ | Describes study design/methods of TLC trial | Randomized multicenter, placebo controlled, double-blind trial | Chelation with DMSA after domestic cleaning with HEPA vacuum and damp cloth wiping | 1854 evaluated, 780 randomized | Multicenter trial (Baltimore, Cincinnati, Columbus, Newark, and Philadelphia) | Children ages 12–33 months, 77% African-American. Most had poor, single mothers and lived in older, poorly maintained residences. | Housing | 20–44 ug/dl | Children ages 12–33 months with blood lead level 20–44 ug/dl on two occasions, living in a residence suitable for lead dust reduction. Recruitment varied by location. Patients were randomized by strata to treatment or placebo. | 36 months | DMSA treatment lasting 26 days, dose based on body surface area; treatment repeated up to 3 times for persistently elevated blood lead level. Domestic cleaning with HEPA vacuum and damp cloth wiping | Behavioral and psychometric assesments, BPb, and a battery of other biochemical tests. | Description of baseline measurements, group characteristics, study methodology. | ND | | Good
Rogan, 2000^144^ | To determine the efficacy of DMSA (TLC trial) | Randomized multicenter, placebo controlled, double-blind trial | Chelation with DMSA after domestic cleaning with HEPA vacuum and damp cloth wiping | 1854 evaluated, 780 randomized | Multicenter trial (Baltimore, Cincinnati, Columbus, Newark, and Philadelphia) | Children ages 12–33 months, 77% African-American. Most had poor, single mothers and lived in older, poorly maintained residences. | Housing | 20–44 ug/dl | Children ages 12–33 months with blood lead level 20–44 ug/dl on two occasions, living in a residence suitable for lead dust reduction. Recruitment varied by location. Patients were randomized by strata to treatment or placebo. | 12 months | DMSA treatment lasting 26 days, dose based on body surface area; treatment repeated up to 3 times for persistently elevated blood lead level. Domestic cleaning with HEPA vacuum and damp cloth wiping | Blood lead level, ZPP | DMSA-treated group blood lead level 11 ug/dl lower at one week. Rebound began at one week and at 7 weeks DMSA group mean blood lead level was 72% of baseline (placebo group mean blood lead level was 88% of baseline). During the six months after initiation of treatment, the DMSA group had a mean blood lead level 4.5 ug/dl lower than the control group. At 12 months mean DMSA group blood lead level is 2.7 ug/dl lower than the control group, but confidence intervals for overlap. At 12 months groups are similar. | No statistically significant difference compared to placebo. Excess noted: trauma, scalp rashes, neutropenia/thrombocytopenia, elevated ALT. | Essentially no effect at 12 months | Good
Rogan, 2001^138^ | To determine whether treatment of blood lead level < 45 ug/dl with chelation improves cognitive outcomes (TLC trial) | Randomized multicenter, placebo controlled, double-blind trial | Chelation with DMSA after domestic cleaning with HEPA vacuum and damp cloth wiping | 1854 evaluated, 780 randomized | Multicenter trial (Baltimore, Cincinnati, Columbus, Newark, and Philadelphia) | Children ages 12–33 months, 77% African-American. Most had poor, single mothers and lived in older, poorly maintained residences. | Housing | 20–44 ug/dl | Children ages 12–33 months with blood lead level 20–44 ug/dl on two occasions, living in a residence suitable for lead dust reduction. Recruitment varied by location. Patients were randomized by strata to treatment or placebo. | 36 months | DMSA treatment lasting 26 days, dose based on body surface area; treatment repeated up to 3 times for persistently elevated blood lead level. Domestic cleaning with HEPA vacuum and damp cloth wiping | Scores on developmental, neuropsychological, and behavioral tests (Bayley Scales of Infant Development II, Wechsler Preschool and Primary Scales of Intelligence-Revices, Developmental Neuropsychological Assesment, Connors' Parent Rating Scale-Revised) | First six months: succimer treatment mean blood lead level 4.5 ug/dl lower than placebo. At 36 months, DMSA group scored on average 1 IQ point lower than the control group, and had slightly worse behavior by parental rating compared to the placebo group. The placebo group fared slightly better on a developmental neuropsychological battery of tests. But overall, there was no statistically significant difference between the two groups. | No statistically significant difference compared to placebo. Excess noted: trauma, scalp rashes, neutropenia/thrombocytopenia, elevated ALT. | Conclusion: chelation < 45 ug/dl not effective | Good
Shannon, 2000^207^ | Determine incidence of adverse affects of low doses of penicillamine for treatment of blood lead level < 04 ug/dl. | Retrospesctive analysis | Chelation with penicillamine | 55 | Urban Children's hospital, Boston MA | Children, mean age 37.4 ± 24.6 months | Housing | 24 ± 5 ug/dl (range 15–37) | Retrospective analysis of medical records of all children who were prescribed d-PCN by the Lead and Toxicology Clinic (LTC) of Children's Hospital, Boston, in 1996. The LTC treatment program receives approximately 1200 annual visits, and works in cooperation with the Massachusetts Childhood Lead Poisoning Prevention Program. | Convenience sample, children who received penicillamine in 1996 | Penicillamine at 15 mg/kg/d administered until blood lead level declined and remained < 15 ug/dl, mean duration of treatment was 77 ± 44 days | Blood lead level, CBC, EP, UA | Mean total white blood cell count fell from 8270 ± 2630/mm⁁3 to 7020 ± 1940/mm⁁3 (p =0.009) during treatment, post-treatment WBC was not significantly differenent than pre-treatment WBC. Mean platelet count fell from 364000 ± 117000 /mm⁁3 to 308000 ± 74000/mm⁁3 during treatment (p<0.001) and was 338000±74000/mm⁁3 after chelation (p=0.02). Rash occurred in 4.5% (N=3) of patients. No cases of abnormal urinalysis. | Rash, depressed WBC and platelet counts. | When compared to results of their previous investigation involving a higher dose, the results suggest that penicillamine at 15mg/kg/d is safer than a higher dose regimen without a significant loss of efficacy. | Case series; non-controlled study.

Abbreviations

ALT = Alanine transferase; AST = Aspartate aminotransferase; CBC = Complete blood count; DMSA = Dimercaptosuccinic acid; EDTA = Ethylenediaminetetraacetic acid; EP = Erythrocyte protoporphyrin; HEPA = High efficiency particulate air; MCH = Mean corpuscular hemoglobin; TLC = Treatment of Lead-Exposed Children study; UA = Urine analysis; WBC = White blood cell count; ZPP = Zinc protoporphyrin

Chelating agents have demonstrated short-term reductions in blood lead levels in children whose pretreatment values ranged from 20 to 70 micro-g/dL in randomized comparative trials, case series studies, and uncontrolled experiments where chelation therapy was often combined with environmental interventions, but these reductions were not sustained over longer periods in the absence of repeated or continuing chelation therapy or environmental interventions.^145^–^152^

In other descriptive studies (case series, uncontrolled trials, etc.) of asymptomatic children with initial blood lead levels ranging from 40 to 471 micro-g/dL, chelating agents reduced blood lead levels substantially, to levels <40–70 micro-g/dL (varying with initial levels) and these reductions were maintained for weeks to years after therapy was discontinued (Table 1).^145,^ ^153^–^157^ Most of these children were also returned to homes that had undergone lead hazard reduction, however, and the effect of this additional intervention was not specifically evaluated.

These data provide good evidence that chelating agents may result in short-term reductions in blood lead levels in children but suggest that these reductions may not be sustained over longer periods in the absence of repeated or continuing chelation therapy or environmental interventions.

### Effect of residential lead hazard control on blood lead levels

Summary: Recent studies of household dust and paint hazard control through cleaning, abatement and education have mixed results. Of the eight controlled studies published since 1995, one has shown a modest but significant decline, five have shown non-significant declines, and two have shown non-significant elevations in blood lead levels among children. Reduced blood lead levels were seen among children with higher baseline lead levels (15+ or 20+ micro-g/dL) in 2 studies (1 meta-analysis, 1 retrospective chart review with no comparison group), but not in children with lower baseline levels. Recent studies differ from older studies in that newer paint hazard control techniques result in lower dust lead levels. Population venous lead-levels have decreased over time, and lead-poisoned children in older studies had higher mean Blood lead levels than in recent studies.

Detailed assessment: (Tables 2 and 3) For most asymptomatic children with elevated lead levels, the primary goal of intervention is to reduce exposure to lead-contaminated paint, dust, and soil in the child's home environment, since these sources account for most excess lead exposure. Newer residential lead-based paint hazard control methods can effectively reduce environmental exposure to lead paint and lead-contaminated dust^23,^ ^158,^ ^159^ in contrast to older strategies that often increased lead exposure during the intervention. These newer techniques, however, can result in an elevation of blood lead in a subset of children immediately following lead control interventions. In an evaluation of HUD-sponsored lead control interventions among fourteen state and local governments, 81 of 869 children (9.3%) had an elevation of >= 5 micro-g/dL. Risk factors associated with post-intervention increases were the number of exterior paint deteriorations, the educational level of the female parent or caregiver and the younger age of the child.^160^

Table 2 Effects of Environmental Modifications on Children's Blood Lead Levels

Author, Year | Title | Aims | Study Design | Type of Intervention | N | Setting | Population/ Risk Factors | Source of Exposure/ Risk Factors | Lead Levels | Main Eligibility Criteria | Duration of Follow-up | Interventions Described | Outcomes Assessed | Results | Adverse Effects | Comments | Quality Rating
Aschengrau, 1994^182^; | The impact of soil lead abatement on urban children's blood lead levels: Phase II results from the Boston lead-in-soil demonstration project; | To study the impact of urban soil lead abatement on children's blood lead levels (The Boston Lead-In-Soil Demonstration Project, 1989-1990); | Randomized environmental intervention; no untreated comparison group | Soil | 152 | Boston neighborhoods with a high incidence of lead poisoning | Children age <4 | Soil | 7 to 24 ug/dL | Children were eligible if they lived in the neighborhoods of Boston with a high incidence of lead poisoning, were under 4 years of age, and had a finger stick blood lead level from 10–20 ug/dL. Children up to age 4 living on the same premises were also eligible. | 2 years | Phase I, 1989-1990: | Three venous blood smples were taken over a 2-year period. During Phase I, samples were obtained before and 10 months after soil or paint abatement. | Pre- and post- soil abatement levels (ug/dL) and change before and after (ug/DL, 95% CI): | ND | Soil abatement effects on blood lead were reported only for selected children in Groups A and B. Group S had mixed interventions. | Not rated; no comparison group
Aschengrau, 1997^183^ | Residential lead-based-paint hazard remediation and soil lead abatement: their impact among children with mildly elevated blood lead levels | To report the Phase II results of the Boston Lead-in-Soil Demonstration Project, which was designed to assess children's blood lead levels and household dust lead levels following (1) lead-based-paint hazard and remediation alone and (2) in combination with soil abatement. | | | | | | | | Also:; 1) the amount of peeling paint was less than 30% of exterior walls of the house or 40% of the exterior walls of adjacent buildings;; 2) the child's house had a yard at least 10 square feet in size that was composed, at least partlyl, of accessible soil and/or grass;; 3) the surface soil lead levels, 1m from the house, averaged at least 1500 ppm;; 4) the house had 8 or fewer apartments;; 5) the child was mobile and had never been lead poisoned; and; 6) the family lived on the premises for at least 3 months and had no plans to move in the near future. | | Study group (n=54) received soil and interior dust abatement and loose paint stabilization | During Phase II, follow-up sampling took place 9 months after soil or paint abatement. | Study group (Phase I, mixed interventions): 13.10, 10.65; -2.44 (-3.32, -1.57)
| | | | | | | | | | | | Comparison group A (n=51) received received interior dust abatement and loose paint stabilization, and Comparison Group B received only loose paint stabilization. | | Group A (Phase II): pre 12.94, post 7.69; change -5.25 (-6.51, -3.99)
| | | | | | | | | | | | Phase II, 1990-1991: | | Group B (Phase II): pre 10.54, post 9.15; change -1.30 (-4.03, +1.26) (includes only children in Groups A and B whose homes were not deleaded during phase II)
| | | | | | | | | | | | Soil abatement was conducted in Comparison Groups A and B, and residential lead-based paint removal was offered to all three groups. | | All groups, all phases combined, irrespective of Phase II deleading status:
| | | | | | | | | | | | Soil abatement: removed 6 inches of top soil from entire yard. | | pre 12.66, post 9.77; change -2.89 (-3.64, -2.13)
| | | | | | | | | | | | Interior dust abatement: vacuuming walls, woodwork, floors, and rugs with a HEPA filter vacuum, and wiping surfaces with wet cloths and furniture with oil-treated cloths | | Soil lead reduction of 2060 ppm is associated with a 2.25 to 2.70 ug/dL decline in blood lead levels. Low levels of soil recontamination 1 to 2 years following abatement indicate that the intervention is persistent.
| | | | | | | | | | | | Lead-based paint remediation: licensed contractors performed the remediation on exterior and interior areas, using containment barriers and HEPA vacuum units. Surfaces were then wet washed and wood floors were coated with polyurethane. | | Paint hazard remediation alone was associated with a blood lead increase of 6.5 ug/dL (p=0.05)
| | | | | | | | | | | | | | Paint hazard remediation combined with soil abatement was associated with an increase of 0.9 ug/dL (p=0.36)
| | | | | | | | | | | | | | Conclusion: lead-based-paint hazard remediation is not an effective secondary prevention strategy among children with mildly elevated blood lead levels.
Aschengrau, 1998^163^ | The impact of low technology lead hazard reduction activities among children with mildly elevated blood lead levels | To determine the effect of low-technology lead hazard reduction activities on children's blood and household dust lead levels. The purpose of the intervention was to reduce children's exposure to household lead hazards by removing lead-contaminated dust and loose paint chips from the window and floor areas and by instructing caregivers to maintain clean window and floor surfaces over the follow-up period. | RCT | Dust | 63 | Boston | Children age <=4 | lead-based paint in home | 16.9 ug/dL | Eligible children:; 1) resided in the city of Boston,; 2) were age <=4,; 3) had a venous blood lead level from 11 to 24 ug/dL,; 4) had no history of lead poisoning (venous lead >=25 ug/dL) or chelation therapy,; 5) were not expected to undergo chelation treatment,; 6) lived on the premises for at least 3 months with no definite plans to move within the next 3 months,; 7) lived in home with lead-based paint in at least two window sills and/or window wells, as determined by sodium sulfied tests,; 8) the home had not been previously deleaded or received lead hazard reduction activities,; 9) the parents spoke English, Spanish, or Cape Verdean creole, and; 10) no other child in the home was already a study participant. | 6 months | Children were screened 1993-1995. Children with severe lead hazards were automatically assigned to an intervention group. | Venous samples were obtained to determine blood lead levels at baseline and an average of 6 months after the intervention. Environmental measurements were made of dust, soil, water, and paint. | Blood level before & after intervention; mean change (ug/dL): | ND | | Fair
| | | | | | | | | | | | Severe hazards were one of the following:; 1) paint chips on any floors,; 2) severe amounts of loose dust or paint chips in any window well, or; 3) holes in walls larger than 1 inch in diameter and positive for lead paint. Children whose homes had lesser hazards were randomly assigned to the intervention group or control group. | | Automatic intervention group (high risk): 17.5, 9.1; -8.4
| | | | | | | | | | | | A one-time intervention was performed by a trained staff member of the Boston Lead Poisoning Prevention Program:; 1) HEPA-vacuuming all window well, window sill, and floor surfaces;; 2) washing window well and window sill surfaces with a trisodium phosphate (TSP) and water solution;; 3) repainting window well and window sill surfaces with primer to seal any chipped or flaking paint; and; 4) repairing holes in walls | | Randomized intervention group: 17.6, 11.5; -6.2
| | | | | | | | | | | | | | Randomized control group: 16.3, 10.4; -5.9
| | | | | | | | | | | | | | Difference between mean changes (95% CI), randomized intervention vs control group: -0.3 (-3.8, +3.3)
| | | | | | | | | | | | | | Automatic intervention vs comparison group -2.5 (-7.0, +2.1)
Campbell, 2003^167^ | Effect of a follow-up professional home cleaning on serial dust and blood lead levels of urban children | To determine the effects of a follow-up professional lead dust cleaning of their homes 18 months after an initial cleaning and commencement of therapy. | Non-randomized trial; followup of chelation RCT (TLC) | Dust | 73 | The Treatment of Lead-Exposed Children Trial, a multicenter, double-blind, RCT in 4 US cities | Toddlers aged 12–34 month at enrollment | lead-based paint in home | 20–44 ug/dL | 780 toddlers with BLLs 20–44 ug/dL enrolled in RCT (TLC study) comparing chelation therapy and placebo. | 9 months (from 15 to 24 months posttreatment, with the 2nd cleaning occurring after 18 and before 21 months | As part of the RCT treatment protocol, the children's homes were professionally cleaned to minimize dust lead exposure. After completion of the treatment phase of the TLC trial, 165 families were offered a second professional dust cleaning of their home. 73 self-selected families participated in the second home cleaning 18 months after the initial cleaning and commencement of therapy. | For this analysis, venous blood samples from 15-mo, 18-mo (just prior to the second cleaning), 21-mo, and 24-mo clinical follow-up visits, from 73 children with homes cleaned and 86 children with homes not cleaned. | There was no significant difference in GM blood lead levels at any clinic visit between children whose homes were cleaned and those whose homes were not cleaned. | ND | Does not report the distribution of chelation vs placebo treatment among children who did or did not receive the 2nd home cleaning. | Fair
| | | | | | | | | | The original study was conducted in Newark NJ, Baltimore MD, Cincinnati OH, and phladelphia PA. In this study, the 165 study families in PHiladelphia were offered a second professional lead dust cleaning of their home, at the 18-month follow-up visit after initiation of treatment. | | | | Geometric mean BLLs, adjusted for month and child, declined monotonically among 73 children whose homes were cleaned a 2nd time. BLLs of the 86 children whose homes did not receive a 2nd cleaning also declined over time, although there was an unexplained increase at the 3-mo postcleaning folow-up visit.
| | | | | | | | | | | | | | BLLs before the cleaning were higher among children in high-exposure homes (GM 18.1 ugdL), compared with those in low-exposure homes (GM 14.5 ug/dL).
| | | | | | | | | | | | | | Stratified by randomized treatment, there were only small differences in BLLs: 18.3 ug/dL and 17.1 ug/dL for children in chelation vs. placebo, in high exposure homes; and 14.5 vs 13.5 ug/dL for chelation vs placebo, in low-exposure homes.
Clark, 2004^160^ | Occurrence and determinants of increases in blood lead levels in children shortly after lead hazard control activities | To examine the effect of lead hazard control strategies on children's blood lead levels immediately after an intervention by the US Department of Housing and Urban Development's (HUD) Lead-Based Paint Hazard Control Grant Program | Cohort study | Lead-based paint and dust hazard control program and survey | 869 children | US Department of Housing and Urban Development's Lead-Based Paint Hazard Control Grant Program | 14 state and local governments included in program | Paint, dust, water, soil, home repair/ remodeling | ND | State or local government's participation in HUD's hazard control program | 6 weeks | Measures blood levels, paint lead levels, dust levels, and parent fills out survey questionnaire (eg: child's age, sex, mouthing behavior, household size, education, etc. Also asked why parents thought that those with ≥ 5 ug/dL increase occurred) (see Appendix for very specific details of these interventions). Intervention strategies categorized as interior, exterior, and site. | Blood tests performed at baseline (within 6 weeks of intervention), immediately after intervention, and later??? 0n children between 6 months and 6 years old. Some data was included from medical records. Capillary and venous sampling. Paint lead determined pre and post intervention using portable x-ray fluorescence analyzers (XRF) at preintervention on about 100 surfaces per dwelling. | Of 869 children tested after intervention, 81 (9.%) had blood lead increases of ≥ 5 ug/dL. Increases ranged from 5–25 ug/dL, average increase 8.4 ug/dL. Logistic regression analysis indicated that 4 factors were significantly associated with increases of ≥ 5 ug/dL:; 1) child's age at pre-intervention (p=0.0061); 2) female caregiver's education (p=0.002); 3) general exterior building condition (p=0.0071); 4) 2nd season of blood sample collection (p< 0.001). As child's age increased, both odds ratio and probability of child showing increase of ≥ 5 ug/dL decreases sharply. In families where the female parent had < high school education, likelihood of ≥ 5 ug/dL was 2.5 times higher than families where female parent had > high school education. As number of exterior deteriorations increased, odds ratio for a ≥ 5 ug/dL was 1.5 higher for 1 deteriorations and 2.3 for 2 or more deteriorations. | ND | | Fair
Farrell, 1998^175^ | Soil lead abatement and children's blood lead levels in an urban setting | To assess the effect of soil lead abatement (1990) among Baltimore children. | RCT | Soil | Enrolled 408 children in 263 houses; 187 completed the study | 2 noncontiguous neighborhoods in Baltimore | Children aged 6 months to 6 years | Paint, soil | Baseline venous level: 11 ug/dL | Subjects were aged 6 months to 6 years, and had been living in the same house (in the selected neighborhoods) for at least 3 months and the family was not planning to move. | 1 year | In summer and fall 1990, loose paint was wet scraped and then cleaned up with a HEPA vacuum. Surfaces were primed and painted twice with latex paint. Strict containment was practiced during the procedure. | Children's venous blood levels before and after soil abatement. | One year postabatement, blood levels in both groups fell below baseline, but there was no significant effect of soil abatement on children's blood lead. Differences between treatment and control groups were not significant in any of the cross-sectional or longitudinal models. Two years postabatement, soil sampling showed significant lead reaccumulation. | ND | | Fair
| | | | | | | | | 54% of properties had soil samples >1000 ppm. | | | Contaminated soil at residences (>500 ppm) was replaced with clean soil. At 90% of the properties, all soil was abated. To prevent soil recontamination, exterior paint was stabilized in both the study and control areas before soil abatement. Children's blood lead levels were characterized before and at 3 months and at 1 year after soil abatement.
| | | | | | | | | | | | Controls received no treatment.
Galke, 2001^170^ | Evaluation of the HUD lead hazard control grant program: early overall findings | To examine the range of interventions used by grant recipients and assess the effectiveness of the HUD Lead Hazard Control Grant Program (1993-1994), based on blood and dust lead data aggregated across the various interventions. | Descriptive study, no comparison group | Dust | 240 children 1212 dwellings | 1212 HUD-treated dwellings in 16 states | Children aged 6 months to 6 years | Half of dwellings were built before 1910 | Median 10 (range 2–48) ug/dL | HUD grantees were required to participated in the evaluation, and also attempted to recruit families residing in the dwellings. Children between age 6 months and 6 years were eligible. | 12 months | Data collection began in 1994. The last dwelling unit was treated in 1997, and the last 12-month data were collected in October 1998. Interior treatment levels were defined by category: spot painting/cleaning, complete painting, painting plus window treatments, plainting plus window abatement, full abatement of lead, total dwellings. Each of the 1212 dwellings had interior treatments, while 79% of the dwellings treatments to the exterior of the building, and 14% had soil treatments. | Blood lead levels (venous or capillary) and dust lead loading were gathered prior to the start of lead hazard control work, within 6 weeks after work was completed, 6 months and 12 months after work was completed. | From preintervention to 12 months postintervention, the geometric mean blood lead level declined from 11.0 to 8.2 (-2.8) ug/dL, a 26% reduction | ND | | Not rated; no comparison group
Haynes, 2002^165^ | The effect of interior lead hazard controls on children's blood lead concentrations: a systematic evaluation | To to use meta-analysis of RCTs of low-cost lead hazard control interventions to determine whether low-cost strategies (defined as <$2500 per housing unit or family) aimed at controlling lead-contaminated dust effectviely prevent childhood lead exposure, as measured by children's blood lead concentration. | Meta-analysis of 4 studies published 1996-2000 | Dust; meta-analysis | 4 studies, total subjects = 533 | NR | NR | NR | 6.7 to 16.9 ug/dL | Eligible articles for meta-analysis:; a) randomized allocation of children to either a control group or intervention group;; b) low-cost interventions defined as <$2500;; c) blood lead levels used as a measured outcome; and; d) trial was not conducted in a community with a continual lead emission source. | 6 to 48 months | Three studies included parental education, two studies provided the families with cleaning supplies or equipment, two provided professional cleaning and one made minor housing repairs. | Blood lead levels at baseline and after intervention, comparing intervention and control groups | The weighted mean change in blood lead in all studies was -0.62 ug/dL (95% CI -1.55 to 0.32). No significant difference between the intervention and control groups for either the educational dust control trials (-0.33 ug/dL, 95% CI -1.4 to 0.74) or the professional dust control trials (-1.52 ug/dL, 95% CI -3.41 to 0.37). Intervention and Control Groups were similar in the % of children >=10 ug/dL, but there were significantly fewer children with >=15 ug/dL and >=20 ug/dL in the treatment group than the control group: 6 vs 14% (p=0.008), and 2 vs 6% (p=0.024) respectively. | ND | Author's conclusion: although low-cost, interior lead hazard control was associated with 50% or greater reduction in the proportion of children who had blood lead concentrations exceeding 15 ug/dL and 20 ug/dL, there was no substantial effect on mean blood lead concentration. | Good
Jordan, 2003^177^ | A randomized trial of education to prevent lead burden in children at high risk for lead exposure: efficacy as measured by blood lead monitoring. | Tested blood lead levels every 4 months. Capillary sampling used until age 1, then venous sampling used unless parent objected. | RCT | Education | 594 mothers of whom 378 children's blood levels were tested | Phillips neighborhood in Minneapolis, MN | Inner-city, economically disadvantaged, ethnically diverse (78% non-Caucasian) | Paint, dust, water, soil, home repair/ remodeling | Before intervention, all levels were < 10 ug/dL | Pregnant women and mothers of young infants were recruited from the Phillips Nieghborhood, a large, inner-city, economically disadvantaged (71% of young children live in poverty), and ethnically diverse (78% persons of color) community. Participants were recruited via door knocking, posters, flyers, information tables at community events, and via referral from cooperating OB and pediatric clinics serving the neighborhood. | 2 years | Mothers randomly assigned to control or intervention. Intervention offerred 20 biweekly in-home educational sessions by same-ethnicity peer educators over a one year period, and quarterly sessions for 2 years following. Sessions included information on lead sources, health consequences, and strategies to reduce exposure. | Tested blood lead levels every 4 months. | A greater percentage of children in intervention group (81%) maintained levels < 10 ug/dL, compared with the control group (73%), although the effect was of borderline significance (p=0.08). 15% of intervention group and 24% of control group had levels between 10–19.99 ug/dL (ns). 4% of intervention group and 2% of control group had levels > 20 ug/dL (ns). Statistical models show that intervention reduced risk of blood lead ≥ 10 ug/dL by approximately 34% (“borderline significance”). | ND | Received cash incentives for participation. Possible confounder of mother's education level that was adjusted for. Authors say education alone is not sufficient to lower exposure. | Fair
| | | | | | | | | | | | | Capillary sampling used until age 1, then venous sampling used unless parent objected. | >90% completed 19 or 20 sessions. 50% completed 1st year of followup sessions; <5% completed 2nd year of followup sessions.
Lanphear, 1999^178^; | Primary prevention of childhood lead exposure: a randomized trial of dust control; Long-term effect of dust control on blood lead concentrations; Environmental lead exposure during early childhood | To assess the effectiveness of a dust control education intervention in preventing children's exposure to lead, as measured by blood lead levels up to 24 months and at 48 months. Interveiews were conducted to estimate nutritional, behavioral, and demographic factors linked with lead exposure. | RCT | Education | 275 | Community-based study in Rochester, New York | Children aged 6 months | NR | 2.9 ug/dL (95% CI 2.7–3.1) at age 6 months | Children and their families were eligible if: they lived in Rochester, NY; they denied having plans to relocate in the next 3 months; and they were between ages 5 to 7 months at the baseline visit. Participants were identified and recruited by using sequential lists of live births from three urban hospitals. | 48 months | After baseline sampling, familes were randomly assigned to an intervention group or a control group. Intervention families received up to 8 visits by a dust control advisor, cleaning equipment and supplies, a detergent containing trisodium phosphate. Control families did not receive any education or interventions. (Calendar years of intervention not reported) | Venous blood lead levels measured at baseline (age 6 months), and at ages 12, 8, and 24, 36, and 48 months of age. | There was no significant difference in blood lead levels by intervention status at 24 months or 48 months. The geometric mean blood lead levels at 24 months of age in the intervention and control groups were 7.3 ug/dL (95% CI 6.6, 8.2) and 7.8 ug/dL (CI 6.9, 8.7) respectively. At 48 months the g.means were 5.9 ug/dL (95% CI 5.3, 6.7) and 6.1 ug/dL (95% CI 5.5, 6.9) | ND | Author's conclusion: dust control through education is not effective in the primary prevention of childhood lead exposure | Fair
Lanphear, 2000^59^; | | | | | | | | | | | | | | There was no significant effect of the intervention on the mean increase in blood lead levels from 6 to 24 months of age (+5.6 ug/dL in the intervention group vs +6.3 ug/dL in the control group p=0.42).
Lanphear, 2002^195^ | | | | | | | | | | | | | | Dust lead levels declined sharply in both the treatment and control groups. There was no significant difference in dust lead levels at 24 months by group, nor a difference in change in dust lead levels from 6 to 24 months by group.
| | | | | | | | | | | | | | Other results (Lanphear, 2002): Dietary iron intake, but not calcium intake, was inversely associated with blood lead levels (p<0.05). Blood lead concentration was over 50% higher in black than in white children (p=0.0001).
Lanphear, 2003^184^ | The effect of soil abatement on blood lead levels in children living near a former smelting and milling operation | To determine the effect of soil abatement for residential soil with mean soil lead concentrations >500 ppm ug/g on blood lead levels in children aged 6–72 months | Two cross-sectional surveys before and after soil abatement | Soil | 198 in 1st survey; 215 in 2nd survey | Population survey in Midvale, Utah | Children | Midvale is a former site of a smelting and milling operation | Baseline mean in children with soil >500 ppm: 5.6 ug/dL, with 11% >=10 ug/dL | Children aged 6–72 months who lived in Midvale, Utah for at least 2 months; excluded children who had taken a prescribed iron supplement in the past 2 months or if there had been a major renovation of their residence during the past 12 months. | N/A | Soil abatement occurred from 1993 to 1996 as follows: a clay cap was constructed over the tailings at the former mining and milling site adjacent to Midvale; yards with soil lead 500 ppm were excavated to 18 inches and backfilled with clean soil. | Surveys in 1989 and 1998 collected venous blood samples from eligibile children, and environmental samples from each residence (dust, paint, soil, water). Intervention group consisted of children whose yards (>500 ppm) were treated; control group were children whose yards (<500 ppm) were not treated. | Change in blood lead (ug/dL) before and after soil abatement: | ND | Soil abatement was associated with a significantly greater reduction in blood lead levels than expected among children ages 6–36 months who had not been exposed to lead-contaminated yards in early childhood. A significant reduction was not seen in children aged 36–72 months. | Not rated: not a true cohort study - different children in cross-sectional surveys before & after soil abatement
| | | | | | | | | Baseline mean in children with soil <500 ppm: 3.0 ug/dL, with 3% >=10 ug/dL | | | | | Intervention group: 5.6 to 3.0 (-3.6), p=0.0001
| | | | | | | | | | | | | | Control group: 3.0 to 2.6 (-1.4), p=0.06
| | | | | | | | | | | | | | Stratifying by age, adjusting for mouthing behavior score and socioeconomic status:
| | | | | | | | | | | | | | Age 36–72 months: 2.3 ug/dL decline (p=ns)
| | | | | | | | | | | | | | Age 6–36 months: 2.5 ug/dL decline (p=0.03)
Leighton, 2003^164^ | The effect of lead-based paint hazard remediation on blood lead levels of lead poisoned children in New York City | To examine the effects of lead hazard remediation and its timing on the blood lead levels of lead-poisoned children. | Retrospective cohort study | Lead paint hazard remediation | 221 | New York City blood lead registry data between July 1994 and December 1996 | Lead-poisoned children | Paint, dust, water, soil, home repair/ remodeling | 20–44 ug/dL | Identified with levels between 20–44 ug/dL in New York City's blood lead registry; had follow-up blood lead test between 10–14 months after initial test; had lead-based paint hazard identified in primary dwelling unit prior to 10–14 month follow-up; only resided at address with hazard; and were not chelated. | 10–14 months | Compared blood levels from baseline to 10–14 month follow-up in homes with remediation and homes without remediation during the follow-up period. | Blood lead levels tested at baseline and followup. Interior dwellings tested using x-ray fluorescence (XRF) analyer. Readings ≥ 0.7 mg/cm^2^ classified as positive and in violation of New York City's Health Code. | Regardless of remediation, mean blood levels declined significantly from 24.3 ug/dL at initial diagnosis to 12.3 ug/dL at follow-up, 50% decline (p<0.01). For 146 children whose homes were remediated, mean blood lead levels declined 53% compared with 41% for the 75 children whose homes were not remediated by the follow-up, a remediation effect of approximately 20% (p<0.01). After adjusting for confounders, remediation effect was 11% (ns). Race was the only factor that confounded the relationship. African American children had higher lead lead levels in follow-up after remediation. White and Asian children has an adjusted mean follow-up blood lead level that was 30% lower than African American children (p<0.01). Effect of remediation appeared to be stronger in younger children (10 – <36 months) than in older children (36–72 months) (p=0.06). Timing of remediation did not have a significant effect on blood lead levels. | ND | Modest decline in remediation versus no remediation groups. Both group's mean blood lead levels decline. Authors think it is due to aging. | Fair
| | | | | | | | | | | | To investigate timing effect of remediation, children were classified into 3 groups depending on time of diagnosis and date of time of remediation as follows: < 3 months, ≥3 – ≤6 months, > 6 months.
| | | | | | | | | | | | Assessed interior components in houses of children < 18 years old identified with blood leadl level ≥ 20 ug/dL.
Rhoads, 1999^161^ | The effect of dust lead control on blood lead in toddlers: a randomized trial | To evaluate the effect of an intervention consisting of maternal education and household dust control measures on blood lead in young children at risk of excessive lead exposure | RCT | Dust | 113 enrolled; final blood levels obtained from 99 | New Jersey urban houses | Mean age of child: 1.7 | Dust | Baseline mean, ug/dL: | Families were recruited by posters and door hangers, or referred by municipal lead program, health care providers, or word of mouth. Those with a child aged 6 months to 3 years were eligible. Homes were evaluated for lead paint. The child's mother had to speak Spanish or English to be eligible. Families were excluded if; 1) no lead paint was found in the home,; 2) the home was in such structural disrepair or was so disorganized that it could not be cleaned effectively,; 3) there was evidence of illicit drug use, firearms, or other major staff safety concerns,; 4) the indiex cihld was in regular day care,; 5) the family was not interested in participating, or; 6) the family could not be recontacted or refused to allow a baseline blood lead sample to be drawn. | 1 year | Consenting families were randomly assigned to a lead exposure reduction group (n=56) or to an accident prevention control group (n=57). Families in the lead intervention were asked to cooperate with a cleaning program in which two study staff members visited every 2 weeks to clean up potentially lead-contaminated dust. These visits typically lasted 2 hours. Floors and carpets were vacuumed with a HEPA vacuum cleaner, and walls, horizontal surfaces, and uncarpeted areas of floor were wet-wiped or mopped with a low-phosphate detergent solution. | Initial and and final blood lead levels (after 1 year); baseline and % decline in sill lead loading | Children's blood lead levels (ug/dL) at baseline / follow-up / change / % change | ND | | Fair
| | | | | | | | | Intervention: 12.4 (SD 5.7) | | | Controls were informed about identified lead paint hazards in their homes and received routine information about lead exposure at the time of enrollment. Controls were given home safety items such as fire extinguishers, smoke detectors, safety latches for cupboards, and first aid kits. They did not receive biweekly visits. | | Intervention: pre 12.4 / post 10.3 / change -2.1 / -17%
| | | | | | | | | Control 11.6 (SD 6.2) | | | Caretakers in both groups were invited to attend 4 to 5 educational sessions during the 1-year intervention | | Control: pre 11.6 / post 11.6 / change +0.1 / +1%
| | | | | | | | | | | | | | Adjustment for baseline blood lead in a regression model provided an estimated intervention effect of 1.9 ug/dL (p<0.05).
| | | | | | | | | | | | | | Mother's final knowledge score was not a highly significant predictor of blood lead change, adjusted for intial blood lead (p<0.01) and number of cleanings (p<0.01).
| | | | | | | | | | | | | | The contribution of the educational intervention could not be clearly distinguished from the effects of cleaning.
Schultz, 1999^179^ | A retrospective examination of in-home educational visits to reduce childhood lead levels. | To examine the changes in blood lead levels of children receiving an in-house education visit and those not receiving an educational visit. | Retrospective cohort study, with reference group | Education | 187 | Milwaukee, Wisconsin Health Department records data | African American, Caucasian, Native American, Asian, other races | Paint, dust, water, soil, home repair/ remodeling | 20–24 ug/dL | Identified with levels between 20–24 ug/dL in Milwaukee Health Department records | 6 months | One in-home educational visit lasting about an hour by a Milwaukee Health Department paraprofessional. Visit stressed importance of reducing lead exposure, nutritional suggestions, and dust clean-up practices, and behavioral changes that can reduce lead exposure. | Blood lead levels tested at baseline and 6 months by capillary and venous sampling. | Intervention group blood lead levels declined by 4.2 micro g/dL or about 21%. | ND | Cost of educational intervention approximately $100 per household visit. | Fair
| | | | | | | | | | | | | | Reference group levels declined by 1.2 ug/dL (6%). Intervention group decline was 3.1 ug/dL (15%) greater than the reference group (between groups difference statistically significant, p<0.001).
Strauss, 2005^171^ | Evaluation of lead hazard control treatments in four Massachusetts communities through analysis of blood-lead surveillance data | 1) To determine whether there are significant differences between dwellings treated under the HUD program and similar untreated dwellings by comparing preintervention to postintervention changes in the distribution of children's BLLs, and; 2) to determine whether it is possible to use existing electronic data resources to make such a determination. | Retrospective cohort study, with untreated reference group | Paint | 1179 | 4 HUD Lead Hazard Control grantees in Massachusetts: Boston, Cambridge, Malden, and Springfield | Children <=36 months | Paint | Preintervention means (ug/dl) Untreated 4.5 Treated 7.0 | Data from 3 sources (local housing programs, local tax assessor offices, and the Massachusetts Childhood Lead Poisoning Prevention Program) was used to identified children that resided in treated and untreated housing units, and their full longitudinal blood-lead history. Children with BLLs > 5 ug/dL before moving into the study housing were excluded. Three sets of matched controls were selected: housing only (based solely upon similar housing characteristics between treated and untreated unitis), Housing-BLL (selected using a balanced weighting of similar preintervention BLLS and similar housing characteristics), and BLL-Only (selected based upon smilar preintervention BLLS, with housing characteristics having relatively little weight). The MA CLPPP provided blood-lead data obtianed between 1993 and 2002. | From 1 year pre-intervention to 3 years post-intervention | Varied by region: | Geometric mean BLLs from before and after treatment were compared for the two sets of housing (treated and untreated dwellings). Blood lead levels were tested 1 year pre-intervention, and 1–3 years post-intervention. | Pre vs. post geometric mean BLLs (% BLL >=10 ug/dL); | ND | There were fewer children measured postintervention in both treated and untreated homes: 66% and 37% in the analysis matching on preintervention BLL. | Fair
| | | | | | | | | | | | Boston & Cambridge: interior treatments included cleaning, complete stabilization, floor treatments, window replacements, and wall enclosure/encapsulation. Exterior treatments included complete paint stabilization plus some enclosre, encapsulation, or removal. | | P-value for change in geometric mean BLL comparing 1 year pre-intervention versus 3 years post, adjusted for time, seasonality, age, and gender, HUD versus untreated: | | Per author: Results indicate a 50% decline in BLLs in treated homes, a significantly larger decline than in untreated homes, after adjusting for the general downward trend in BLLS observed in the general population for the last several years.
| | | | | | | | | | | | Malden, interior: Removing all lead-based paint and enclosing or encapsulating all lead-based paint. | | With controls matched on housing criteria only:
| | | | | | | | | | | | Springfield, interior: Removing all lead-based paint on mouthable and movable impacted (both friction and friction and impact) surfaces and loose leaded surfaces. | | HUD-treated: 7.04 (42.7%) vs.3.54 (13.2%)
| | | | | | | | | | | | Malden & Springfield, exterior: Enclose, encapsulate or remove all lead-based paint. | | Untreated control: 4.57 (19.7%) vs 3.45 (10.0%)
| | | | | | | | | | | | | | P<0.001
| | | | | | | | | | | | | | With controls matched on a combination of preintervention BLL and housing information:
| | | | | | | | | | | | | | HUD-treated: 7.07 (42.8%) vs. 3.57 (12.5%)
| | | | | | | | | | | | | | Untreated control: 5.76 (29.1%) vs 3.96 (15.9%)
| | | | | | | | | | | | | | P=0.116
| | | | | | | | | | | | | | With controls matched on preintervention BLL information:
| | | | | | | | | | | | | | HUD-treated: 7.07 (42.9%) vs 3.59 (12.6%)
| | | | | | | | | | | | | | Untreated control: 6.62 (36.9%) vs. 4.28 (16.0%)
| | | | | | | | | | | | | | P=0.015
Swindell, 1994^168^ | Home abatement and blood lead changes in children with class III lead poisoning | To study the effect of home abatement on blood lead levels in children from central Massachusetts who had not undergone chelation therapy and whose homes were abated between 1987 and 1990, before and after abatement policies became more stringent in 1988 | Retrospective chart review; no comparison group | Paint; dust | 132 | Worcester County, central Massachusetts | Children with high lead levels, mean age 35 months, range 12–91 months 52% boys | Lead paint shed from deteriorating surfaces | Preabatement level = 26.0 (+-6.5) ug/dL | Massachusetts Dept of Public Health records were reviewed of all children from central MA with confirmed venous blood lead levels >=25 ug/dL from 1987 through 1990. Eligibility criteria:; 1) the child's principal dwelling must have been abated during they years 1987-1990;; 2) the child must have had at least one venous blood lead determination within 6 months prior to the abatement;; 3) the child must have had at least one venous blood lead determination 2 weeks to 6 months following abatement;; 4) the child must not have received chelation therapy during that time period; and; 5) the child must have lived in the same dwelling throughout the study period. | 2 weeks to 6 months following abatement | Abatement policies in Massachusetts from 1987-1990. In 1988, there were no regulations regarding the abatement process itself: paint removal could occur by sanding, scraping, or torching, with no formal dust-control methods or clean procedures mandated. Since 1988, more stringent regulations were enacted to control dust exposure from abatement. | Venous blood lead levels measured 2 weeks to 6 months following abatement. | Mean blood lead levels changed from 26.0 ug/dL at baseline to 21.2 ug/dL (p<0.001). | ND | The effect of intervention was absent in children with initial blood lead levels of less than 20 ug/dL. | Not rated; no comparison group
| | | | | | | | | | | | | | The % of children with reduced blood lead levels varied with baseline blood lead levels. 97% of children with baseline blood lead levels >=30 ug/dL had reductions within 1 year; 81% of those with baseline blood lead levels from 20–29 ug/dL had reductions, but only 35% of subjects with baseline blood lead levels <20 ug/dL had decreases. In this group, mean blood lead levels increased following abatement, from 16.7 to 19.2 ug/dL (p=0.053) | | No control group.
| | | | | | | | | | | | | | There was no meaningful change in pre- to postabatement levels by calendar year of abatement.
Taha, 1999^162^ | Low-cost household paint abatement to reduce children's blood lead levels | To examine the effectiveness of low-cost lead household paint abatements, which treated deteriorated surfaces instead of the entire house, on the blood lead levels of young, urban children: an evaluation of environmental and educational interventions in 1994. | Retrospective cohort study | Paint; dust | 42 eligible; data analyzed for 37 | Milwaukee, WI | Intervention: | household paint | 28.8 ug/dL | Milwaukee households that met the following criteria:; 1) a child between the ages of 6 months and 6 years was a resident during initial and folow-up blood lead tests,; 2) the child's initial blood lead level was between 25 and 44 ug/dL inclusive and the child was not chelated; 3) a low-cost abatement was performed, and; 4) the child had a follow-up blood lead taken at least 28 days after the abatement was completed. | Mean 69 days after abatement | Education: A public health nurse visited the household and educated the family about lead poisoning and risk reduction activities that would protect the child, such as advising on nutrition, frequent handwashing, and strict cleaning procedures to reduce dust and paint chips. | The analysis used 1990-1994 data on 13,476 children to perform statistical adjustment for seasonal fluctuations. | Initial unadjusted mean blood lead level was 31.8 ug/dL. Follow-up blood lead was taken on average 69 days after abatement, and 172 days after the initial sample. After treatment, the average blood lead levels were 24.6 ug/dL, representing a decrease of 6.2 ug/dL or 22%. | ND | | Fair
| | | | | | | 86.4% aged 1–3 | | | Controls: 65 children selected retrospectively from the Milwaukee Health Department who resided in the same area as the intervention children per zip code, were aged 6 months to 6 years, lived in the same unabated home in 1994 during which 2 blood lead tests were taken, and had an initial blood lead of 25–44 ug/dL with a follow-up blood lead taken at least 28 days later. | | Environmental: An inspector conducted a risk assessment. Necessary treatments to deteriorated painted surfaces were performed by a certified lead abatement contractor. All households had chipping, deteriorating, flaking, or peeling lead paint. Deteriorated window wells were enclosed with aluminum or vinyl. other painted surfaces were wet-scraped and repainted with latex paint. | | After adjusting for season and age of child, the average decrease was 6.0 ug/dL, an 18% reduction.
| | | | | | | 64.9% male | | | | | | | Adjusted blood lead levels, ug/dL: initial / follow-up / change / percentage change
| | | | | | | 75.7% black | | | | | | | Intervention children (n=37): 28.8 / 22.8 / -6.0 (p=0.05) / -18.0%
| | | | | | | 5.4% white | | | | | | | Control children (n=65): 31.1 / 29.5 / -1.6 (p=ns) / -1.8%
| | | | | | | Control:
| | | | | | | 63.1% aged 1–3
| | | | | | | 41.5% male
| | | | | | | 92.3% black
| | | | | | | 4.6% white
Yiin, 2003^166^ | Impact of home carpets on childhood lead intervention study (CLEARS) | To examine the reduction in children's blood lead level achieved in homes with and without substantial carpeting on floors. | RCT | Dust | 39 | New Jersey urban houses | Children aged 6–36 months | NR | 10.61 ug/dL | Children aged 6–36 months enrolled in Childhood Lead Exposure and Assessment Reduction Study (CLEARS). | 12 months | Participating families were randomized to receive intervention or control. | Wipe and vacuum samples of household dust were obtained, and blood lead specimens were collected, at baseline and again after 12 (+-3) months of participation. | Mean baseline blood lead level (ug/dL): 10.53 in carpeted group, 10.66 in uncarpeted group | ND | Cleaning resulted in a significant reduction in blood lead level in uncarpeted households, but not in carpeted households. | Fair
Parent study: | | | | | | | | | | | | Intervention group: offered home cleaning services every 2 weeks over a 12-month period. | Families were categorized by carpet status: having carpets in >50% (n=16) vs not (n=23). | Reduction in intervention group:
Rhoads, 1999^161^ | | | | | | | | | | | | Control group was assisted with home safety and accident prevention | | Carpeted: -8% (p=ns), final blood lead level 9.69 ug/dL
| | | | | | | | | | | | | | Uncarpeted: -26% (p=0.004), final blood lead level 7.90 ug/dL
| | | | | | | | | | | | | | The blood lead reductions were linearly related to the number of cleaning visits in the uncarpeted homes (r=0.67, p<0.001), whereas no significant relation was found in the carpeted homes (r=0.04, p=0.885)

Abbreviations

ND =Failure to describe

NR =Absence

RCT = Randomized controlled trial

SD = Standard deviation

Table 3 Summary of Effects of Environmental Modifications on Children's Blood Lead Levels

Author, Year (Quality) | Study Design | Type of Intervention | Years conducted | N | Age | Duration of Follow-up | Baseline blood lead level | Blood lead level (ug/dL) by group (Treatment vs. Control): Initial / final / change | Summary of effect (+ indicates benefit)
Aschengrau, 1994^182^; | Randomized environmental intervention; no untreated comparison group | Soil | 1989-1990 | 152 | <=4 | 2 years | 7 to 24 ug/dL | T1: 13.10 / 10.65 / -2.44 (95% Cl -3.32, -1.57) | N/A
Aschengrau, 1997^183^ | | | | | | | | T2: 12.94 / 7.69 / -5.25 (95% Cl -6.51, -3.99)
(N/A) | | | | | | | | T3: 10.54 / 9.15 / -1.30 (95% Cl -4.03. +1.26)
| | | | | | | | All Ts combined: 12.66 / 9.77 / -2.89 (95% Cl -3.64. -2.13)
| | | | | | | | C: None
Aschengrau, 1998^163^ | RCT | Dust, paint | 1993-1995 | 63 | <=4 | 6 months | 16.9 ug/dL | T1 (high blood lead level, not randomized): 17.5 / 9.1 / -8.4 | No effect
(Fair) | | | | | | | | T2 (rand.): 17.6 / 11.5 / -6.2
| | | | | | | | C (rand.): 16.3 / 10.4 / -5.9
| | | | | | | | T1 vs C: -0.3 (95% CI -3.8, +3.3)
| | | | | | | | T2 vs C: -2.5 (95% CI -7.0, +2.1)
Campbell, 2003^167^ | Non-randomized controlled trial; followup at the Philadelphia site of TLC, a chelation RCT | Dust | NR | 73 | 12–34 months | 3–6 months posttreatment | 20–44 ug/dL | No significant difference in geo.mean BLLs at any clinic visit between children whose homes were cleaned vs. those whose homes were not cleaned. BLLs declined among both groups. | No effect
(Fair)
Clark, 2004^160^ | Observational, no untreated comparison group | Dust, paint | NR | 869 children | 6 months to 6 years | 6 weeks | ND | Mean change after intervention +8.4 ug/dL Predictors of blood lead level increase of >5 ug/dL: | N/A
(N/A) | | | | | | | | Child's age at baseline (p=0.0061)
| | | | | | | | Mother's education (p=0.002)
| | | | | | | | Exterior building condition (p=0.0071)
| | | | | | | | Season of sample collection (p<0.001)
Farrell, 1998^175^ | RCT | Soil | 1990 | Enrolled 408 children in 263 houses; 187 completed the study | 6 months to 6 years | 1 year | 11 ug/dL | T: 12.1 (1988) / 9.7 (1991) | No effect
(Fair) | | | | | | | | C: 10.9 (1988) / 8.4 (1991)
| | | | | | | | Treatment effect, adjusted for effects of time, seasonality, SES, age, and mouthing behavior
| | | | | | | | T (pre - post): 0.030 (SE 0.034)
| | | | | | | | C (pre - post): 0.075 (SE 0.036)
| | | | | | | | T vs C: -0.045 (SE 0.037)
Galke, 2001^170^ | Descriptive study, no comparison group | Dust | 1994-1997 | 240 children 1212 dwellings | 6 months to 6 years | 12 months | Median 10 ug/dL | T: 11.0 / 8.2 / -2.8 | N/A
(N/A) | | | | | | | | C: none
Haynes, 2002^165^ | Meta-analysis | Dust, paint; meta-analysis of RCTs | NR | 4 studies, total subjects = 533 | NR | 6 to 48 months | 6.7 to 16.9 ug/dL | Weighted mean change, T vs C (95%Cl): | No effect overall; tx effects seen at higher lead levels
(Good) | | | | | | | | 2 educational dust control trials: -0.33 (-1.4, 0.74)
| | | | | | | | 2 professional dust control trials: -1.52 -3.41, 0.37
| | | | | | | | All trials:
| | | | | | | | % >=10 ug/dL in T vs C: similar
| | | | | | | | % >=15 ug/dL in T vs C: 6 vs 14% (p=0.008)
| | | | | | | | % >=20 ug/dL in T vs C: 2 vs 6% (p=0.024)
Jordan, 2003^177^ | RCT | Education | NR | 594 mothers of whom 378 children's blood levels were tested | Birth to 36 months | 2 years | < 10 ug/dL | T vs C | No effect
(Fair) | | | | | | | | % who maintained blood lead level < 10 ug/dL: 81 vs 73% (p=ns)
| | | | | | | | % with blood lead level 10–19.99: 15 vs 24% (p=ns)
| | | | | | | | % with blood lead level >20 ug/dL: 4 vs 2% (p=ns)
Lanphear, 1999^178^; | RCT | Education | NR | 275 | 6 months at baseline, followed to age 48 months | 48 months | 2.9 ug/dL | Change from age 6 to 24 months: | No effect
Lanphear, 2000^59^; | | | | | | | | T: 2.8 / 7.3 / +5.6 (sic)
Lanphear, 2002^195^ | | | | | | | | C: 2.9 / 7.8 / +6.3 (sic)
(Fair) | | | | | | | | T vs C: (p=ns)
Lanphear, 2003^184^ | Two cross-sectional surveys before and after soil abatement | Soil | 1993-1996 | 198 in 1st survey; 215 in 2nd survey | 6–72 months | N/A (cross-sectional) | 5.6 ug/dL | T: 5.6 / 3.0 / -3.6, p=0.0001 | Effect seen only in young children who had not been exposed
(N/A) | | | | | | | | C: 3.0 / 2.6 / -1.4, p=0.06
| | | | | | | | Stratifying by age, adjusted for mouthing behavior score and socioeconomic status:
| | | | | | | | Age 36–72 months: 2.3 ug/dL decline (p=ns)
| | | | | | | | Age 6–36 months: 2.5 ug/dL decline (p=0.03)
Leighton, 2003^164^ | Retrospective cohort study | Dust, paint | 1994-1997 | 221 | 6 months to 6 years | 10–14 months | 20–44 ug/dL | Decline occurred regardless of remediation: | No effect
(Good) | | | | | | | | 24.3 / 12.3 / -12 (p<0.01)
| | | | | | | | T: 24.6 / 11.6 –53%
| | | | | | | | C: 23.8 / 13.9 –41%
| | | | | | | | Remediation effect adjusted for race: 11% (p=ns)
| | | | | | | | Effect of remediation tended to be stronger in younger children (10 to <36 months) vs 36–72 months (p=0.06)
Rhoads, 1999^161^ | RCT | Dust | NR | 113; final blood lead level obtained from 99 | 6 to 36 months | 1 year | 12 ug/dL | T: 12.4 / 10.3 / -2.1 | +
(Fair) | | | | | | | | C: 11.6 / 11.6 / +0.1
| | | | | | | | T vs C: -1.9 ug/dL (p<0.05)
| | | | | | | | Adjustment for baseline blood lead level
Schultz, 1999^179^ | Retrospective cohort study | Education | 1994 | 187 | Mean age 3.35 | 6 months | 20–24 ug/dL | Change in blood lead level, T vs C: -4.2 vs -1.2 (p<0.001) | +
(Fair)
Strauss, 2005^171^ | Retrospective cohort study | Dust, paint | 1993-2002 | 1179 | <=36 months | 3 years | 4.5–7.0 ug/dL | Geometric mean BLLs; P-value for treated vs control, adjusted for time, seasonality, age, and gender, | +
(Fair) | | | | | | | | Matched on preintervention BLL:
| | | | | | | | T: 7.07 / 3.59 / -3.48
| | | | | | | | C: 6.62 / 4.28 / -2.34
| | | | | | | | P = 0.015
| | | | | | | | Matched on preintervention BLL and housing criteria combined:
| | | | | | | | T: 7.07 / 3.57 / -3.50
| | | | | | | | C: 5.76 / 3.96 / -1.80
| | | | | | | | P = 0.116
Swindell, 1994^168^ | Retrospective chart review; no comparison group | Dust, paint | 1987-1990 | 132 | mean 35 months, range 12–91 months | 2 weeks to 6 months following abatement | 26 ug/dL | T: 26.0 / 21.2 / -4.8 (p<0.001) | + only if baseline blood lead level >=20
(N/A) | | | | | | | | T group with baseline <20 ug/dL: 16.7 / 19.2 / +2.5 (p=0.053)
| | | | | | | | C: none
| | | | | | | | Stratified by baseline blood lead level, reductions within 1 year occurred in
| | | | | | | | 97% with baseline >=30
| | | | | | | | 81% with baseline 20–29
| | | | | | | | 35% with baseline <20
Taha, 1999^162^ | Retrospective cohort study | Dust, paint | 1994 | 42 eligible; data analyzed for 37 | 6 months and 6 years | Mean 69 days after abatement | 28.8 ug/dL | Adjusted for season and age of child: | +
(Fair) | | | | | | | | T: 28.8 / 22.8 / -6.0 (p=0.05)
| | | | | | | | C: 31.1 / 29.5 / -1.6 (p=ns)
Yiin, 2003^166^ | Observational study, part of RCT (Rhoads, 1999) | Dust, carpeted vs uncarpeted | NR | 39 | 6 to 36 months | 12 months | 10.61 ug/dL | Carpeted: 10.53 / 9.69 / -0.84 | N/A
Parent study: | | | | | | | | Uncarpeted: 10.66 / 7.90 / -2.76
Rhoads, 1999^161^ | | | | | | | | Significance wrt # cleaning visits:
(Fair) | | | | | | | | Carpeted: p=ns
| | | | | | | | Uncarpeted: p<0.001

Abbreviations

N/A=Not applicable; NR=Not reported; RCT=Randomized controlled trial

Pre-1996 retrospective cohort studies, case series, and uncontrolled experiments suggest that there is a modest decline (4–10 micro-g/dL) in mean blood lead levels in children with initial blood lead levels ≥ 25 micro-g/dL. More recent studies of newer lead-based paint hazard control techniques that included an untreated comparison group found small beneficial effects^161,^ ^162^ or no effects of intervention.^163,^ ^164^

A meta-analysis of 4 randomized controlled trials conducted between 1996 and 2000, found that interventions had no effect on mean blood levels (-0.62 micro-g/dL, 95% CI -1.55 to 0.32), but that there were significant reductions in the proportion of children who had blood lead concentrations exceeding 15 micro-g/dL (6% vs. 14%, p=0.008) and 20 micro-g/dL (2% vs. 6%, p=0.024) in the intervention group compared with the controls.^165^

Two of these 4 trials evaluated dust control and two evaluated the provision of education and equipment to families. The earlier of the two trials of dust control (1998) evaluated one-time professional dust control and window sill paint sealing in homes of children aged 4 or younger, with mean blood lead of 16.9 micro-g/dL.^163^ There were similar reductions in blood levels in the intervention and control groups (-6.2 vs. -5.9 micro-g/dL) 6 months after abatement. In the 2nd randomized trial (1999), conducted in Jersey City, New Jersey, investigators recruited children aged 6 to 36 months who had lead paint in the home. Families (n=113) were randomized to a lead exposure reduction group or to an accident prevention control group. In the lead exposure reduction group, staff members visited the home every two weeks and spent about 2 hours cleaning up dust. After 1 year, there was a small but statistically significant difference in blood lead change between intervention and control groups, adjusted for baseline lead levels (-2.1 vs. +0.1 micro-g/dL, p<0.05).^161^ A subanalysis of this trial found that among 39 homes that received the intervention, only children in uncarpeted homes experienced a significant reduction in blood lead levels. Mean blood lead level decreased by 2.76 micro-g/dL (p=0.004) among children in uncarpeted homes, compared with a reduction of 0.84 micro-g/dL (p=ns) among children in carpeted homes.^166^

A follow-up study in urban children in a trial of chelation therapy vs. placebo examined the effects of a second professional lead dust cleaning of homes 18 months after an initial cleaning and commencement of therapy.^167^ All homes in the Philadelphia site (n=165) of the TLC trial^144^ were offered a second professional cleaning, and subject participation in the follow-up intervention was voluntary rather than randomized. The mean BLL at study initiation was 26 micro-g/dL, and the randomized trial found no difference in blood lead levels between the chelation and placebo groups. The mean BLL was 15.7 micro-g/dL at the second cleaning visit, and 6 months later there was no difference in blood lead levels between children whose homes were cleaned (n=73) and those whose homes were not cleaned (n=86). The report of the follow-up cleaning trial did not stratify results by the original treatment assignment of the subjects, so the effects of the combined interventions cannot be compared with an untreated group.

A 2003 retrospective cohort study identified children listed in the New York City child blood lead registry and compared blood levels before and 10–14 months after remediation with those of a control group that did not have remediation.^164^ Mean blood levels declined significantly from 24.3 micro-g/dL to 12.3 micro-g/dL at follow up, regardless of remediation. After adjusting for confounders, the remediation effect was 11% (p=ns). Race was identified as the only confounding factor, and white and Asian children had an adjusted mean follow-up blood lead level 30% lower than African American children (p<0.01). The effect of remediation appeared to be stronger in younger children (10 –<36 months) than in older children (36–72 months.) Another retrospective cohort study that evaluated in-home counseling, combined with professional lead paint remediation, compared lead levels in children aged 6 months to 6 years with mean blood lead of 28.8 micro-g/dL with similar children who did not receive the intervention.^162^ Follow-up blood lead was measured on average 69 days after abatement, 172 days after the initial sample. After adjusting for season and age of the child, the treatment group blood lead decreased 6.0 micro-g/dL from 28.8 to 22.8, and the effect of treatment was significant (p<0.05). The comparison group mean blood lead decreased 1.6 micro-g/dL from 31.1 to 29.5 (p=ns).

In a retrospective study that measured blood lead levels in children whose homes were abated between 1987 and 1990, before and after abatement policies in Massachusetts became more stringent in 1988, the mean blood lead decreased from 26.0 micro-g/dL at baseline to 21.2 micro-g/dL (p<0.001) measured between 2 weeks to 6 months post abatement. Reductions were only seen, however, among children whose baseline blood lead levels were greater than 20 micro-g/dL. This study found no meaningful change in pre to post abatement levels by calendar year of intervention.^168^ The effect of different housing policies on the risk of subsequent lead exposure in homes where a child with elevated blood lead had resided in the past was demonstrated in adjacent geographic regions of two northeastern states. Approximately eight years later, the risk of identifying at least one child with an elevated blood lead level (≥10 micro-g/dL) was four times greater in the state with less stringent housing-based lead poisoning prevention policies.^169^

A study of 1212 HUD dwellings that received interior treatment for lead hazard control in thirteen states from 1994 to 1998 reported a mean 2.8 micro-g/dL reduction in children's (n=240) blood lead levels at 12 months postintervention, from a median level of 10 micro-g/dL at baseline.^170^ The effect of treatment in these studies was not compared with an untreated population. Another study of HUD dwellings in four Massachusetts communities found a significantly larger decline in blood lead levels between 1993 and 2002 among children in treated homes than in untreated homes, matching on preintervention BLL. Children's BLLs decreased from 7.07 and 6.62 micro-g/dL to 3.59 and 4.28 in the treated and untreated homes respectively (p=0.015). The study adjusted for time and seasonality to account for the downward trend in BLLs observed among children in the general Massachusetts population, from 5.9 micro-g/dL in 1994 to 3.2 ug/dL in 2002.^171^

These trials also highlight important problems with using lead-paint hazard control as the sole method to reduce lead exposure. Poor inner-city families tend to move frequently, so that treating the current residence may have limited long-term benefit to the child, although benefit may accrue to other children moving into that residence. In the Jersey City study, for example, approximately 30% of the randomized families moved during the 12-month follow-up period.^161^ Residential lead-paint hazard control is costly and labor-intensive, resulting in low rates of intervention, especially in poor communities.^22,^ ^172^ Lead dust is ubiquitous and highly mobile, so that recontamination by nearby lead sources, including soil lead, may occur after lead-paint hazard control efforts take place in a dwelling.^158,^ ^173^–^175^ These problems indicate a need for additional individual interventions, as well as more comprehensive community-based interventions, to reduce household lead exposure. Unfortunately, available data about programs that employ multiple interventions are sparse.^157,^ ^160^

The small effect noted in studies evaluating lead-paint hazard control methods may be attributable in part to recontamination of the dwelling by nearby lead sources and from subsequent deterioration of painted surfaces.^158,^ ^173,^ ^174^ Several studies have evaluated measures designed to reduce ongoing lead-dust contamination from lead-contaminated paint and soil. In a nonrandomized controlled trial among children with blood lead levels of 30–49 micro-g/dL, having a research team wet-mop all lead-contaminated interior surfaces twice a month with a high-phosphate detergent cleanser resulted in significantly greater adjusted declines in mean blood lead levels of children in intervention households compared to children in control households (6.9 vs. 0.7 micro-g/dL) at 1-year follow-up.^176^

### Counseling and education interventions

Summary: Overall, there is insufficient evidence to determine whether education and counseling improves outcomes among children with moderately elevated blood lead levels. Blood lead reductions of varying magnitude occurred in children whose families received no intervention.

Detailed assessment: There have been no controlled studies to evaluate whether counseling families to perform cleaning would be as effective in reducing blood lead levels as professional cleaning. Two randomized controlled trials that administered counseling alone,^177^ or with the provision of cleaning supplies,^178^ found no significant effects of the intervention on children's blood lead levels. A retrospective cohort study of children with blood lead of 20–24 micro-g/dL found that a one-time in-home educational visit was associated with a greater reduction in blood lead after 6 months, compared with households that did not receive an educational visit (-4.2 micro-g/dL vs. -1.2 micro-g/dL, p<0.001).^179^ In one uncontrolled experiment, the families of 78 children with blood lead levels of 10–35 micro-g/dL, who were living in the vicinity of a defunct lead smelter, received intensive (30–45 minutes) in-home education and literature on prevention of lead exposure.^180^ The mean blood lead levels in the 51 (65%) children who had follow-up blood lead levels at 4 months declined from 15.0 to 7.8 micro-g/dL (and maximum levels from 35.0 to 12.7 micro-g/dL). Without concurrent controls, it is not possible to determine how much regression to the mean and seasonal and age variations contributed to these reductions in blood lead levels. There is also evidence that clinician counseling at the worksite to reduce lead dust ingestion by workers (e.g., through personal hygiene practices) can significantly reduce mean blood lead levels at 1-year follow-up,^181^ but this study also lacked controls and may not be generalizable to the residential setting.

### Soil abatement

Summary: Recent studies of soil remediation in residential areas have shown only modest or non-significant effects.^175,^ ^182,^ ^183^ Soil remediation in communities near lead mining, milling, or smelting operations may have a beneficial effect but was not considered within the scope of review.

A third focus of residential lead hazard control is exposure to soil lead. In a randomized controlled trial^173^ of young children with initial blood lead levels of 7–24 micro-g/dL, extensive soil abatement, one-time dust abatement, and removal of loose interior paint resulted in a statistically significant reduction in mean blood lead levels of 1.2–1.3 micro-g/dL compared to loose paint removal alone. This clinically insignificant decline was associated with a substantial reduction in soil lead from a median 2,000 to 105 ppm. Preliminary results of the U.S. Environmental Protection Agency's Three City Urban Soil Lead Abatement Demonstration Project similarly suggest that substantial declines in soil lead cause only modest or no reduction in mildly elevated blood lead concentrations.^174,^ ^175,^ ^182,^ ^183^ The small effect was due at least in part to rapid recontamination with dust lead in households undergoing soil abatement. Among children living near a closed lead smelter, only 3% of the variance in blood lead levels was attributable to soil lead.^180^

An important potential public health benefit of residential lead hazard control is its effect on the lead levels or clinical outcomes of other children who live in the same household as a child identified with elevated lead levels, or who subsequently move into the remediated residence. Based on the biokinetics of lead,^21^ it is reasonable to believe that environmental interventions conducted before children are exposed are likely to prevent increases in blood lead levels more effectively than the same interventions in children who have already been exposed. Cross-sectional surveys before and after soil abatement in the vicinity of a former smelting and milling operation observed a statistically significant reduction in blood lead levels among children aged 6–36 months who had not been exposed to lead-contaminated yards in early childhood. A significant reduction was not seen in children aged 36–72 months.^184^

### Effect of nutritional interventions on blood lead levels

Summary: There is insufficient evidence to determine whether nutritional interventions are an efficacious route to lowering children's blood lead levels.

Detailed assessment: In most settings, neither residential lead-based paint nor dust hazard control nor chelation therapy is routinely offered to children with blood lead levels <20 micro-g/dL, but some experts have recommended offering these children dietary counseling to reduce their blood lead levels.^124^ There is limited, preliminary, and somewhat contradictory evidence that correcting such nutritional inadequacies will reduce blood lead levels or prevent further increases in children, depending on the nutritional intervention under investigation (Tables 4 and 5).^157,^ ^185^–^194^

Table 4 Effects of Nutritional Interventions on Children's Blood Lead Levels

Author, Year | Nutritional Category | Study Design | Population | N | Initial Blood Levels | Intervention Described | Results (Significance levels) | Adverse Effects (NR for absence; ND for failure to describe) | Comments | Quality Rating
Dalton, 1997^185^ | Calcium | Randomized controlled trial | Infants aged 3.6 – 6 months in Lawrence, MA. High proportion of low income families. Data collected 1991-1993. Majority Latino (> 90%). | 103 | 0.12 micro mol/dL - 0.07 micro mol/dL | Infants randomized to receive iron-fortified infant formula (465 mg Ca and 317 mg P/L) or the same formula with added calcium glycerophosphate (1800 mg Ca and 1390 mg P/L) for 9 months. Infants analyzed every month. Blood samples were taken at baseline, 4 and 9 months to measure BPbs, serum ferritin, total iron binding capacity, erythrocyte protoporphyrin, and hematocrit. Calcium in treatment group was 4 times greater than control group. | There were no significant differences by treatment group in mean or median change from baseline of serum ferritin, total iron binding capacity, erthrocyte protoporphyrin, or hematocrit at 4 and 9 months after enrollment. Incidence of iron deficiency was similar for both groups and no infant developed iron deficiency anemia during the trial. | ND | Healthy, full term infants fed iron-fortified formula do not need to worry about the inhibitory effect of calcium and phosphorus on iron absorption. | Good
| Iron
| Phorphorus
Gallicchio, 2002^186^ | Calories | Prospective cohort study | Children, age 1 (approximately), from low income families, living in urban houses built prior to 1950. 85% African American. | 205 | mean 4.0 micro g/dL (range 1–19 micro g/dL) 4.9% ≥ 10 micro g/dL | Measured children's venous BPbs, nutritional status including total caloric intake, total fat intake, protein, carbohydrates, saturated fat, monounsaturated fat, polyunsaturated fat, cholesterol, animal fat, vegetable fat, calcium, iron, magnesium, phosphorus, zinc, vitamin D, and vitamin C (using Children's Nutrition Questionnaire designed by Harvard University's School of Public Health), and amount of lead exposure (from dust samples) with followup measurements after a year. | Statistically significant positive associations (p<0.05) were found between blood lead and calories, total fat, saturated fat, and monounsaturated fat. Statistically significant negative associations (p<0.05) were found between blood lead and carbohydrates and vitamin C. | ND | | Fair
| Carbohydrates | | | | | | After multiple linear regression analyses, statistically significant positive associations were found between blood lead and total fat (p=0.03) as well as blood lead and saturated fat (p=0.02), independent of lead exposure and age of the child. Total caloric intake was found to be a marginally significant effect modifier of the association between lead exposure and blood lead (p=0.06).
| Fat
| Vitamin C
Hammad, 1996^187^ | Iron | Cross-sectional study | Children from 9 months - 5 years old cared for at University of Maryland at Baltimore Pediatric Ambulatory Center. Low income, inner-city families. | 299 | NA | Nutritional status (using modified, unvalidated for children, but validated for adults, Gladys Block food frequency questionnaire), socioeconomic aspects, medical history, and potential sources of lead exposure were assessed. Blood samples were evaluated for BPbs, serum iron (ferritin), free erythrocyte photoporhyrin, calcium, and hematocrit. | Average blood lead was 11.4 micro g/dL. After adjusting for confounders using multiple linear regression models, a negative association between blood lead and dietary iron intake was found (p=0.03). No association was found between blood lead and serum iron. | ND | | NA
Haynes, 2003^196^ | Calcium | Prospective cohort study | Children living in Rochester, NY and were 5–7 months old at baseline visit. Low income families. (same participants in Lanphear, 2002) | 275 (245 at 24 month followup; 239 with adequate blood samples) | NA | Assessed BPbs of children at 6, 12, 18, and 24 months of age. Nutritional intake was also measured at these same timepoints by a trained interviewer asking the caretaker questions about child's dietary intake using a food frequency checklist (Willet, 1990). Breast milk was incorporated into checklist. | Calcium intake was inversely associated with children's blood lead (p=0.03) in a multivariate model that included VDR Fok 1 genotype as an independent variable. | ND | No significant association was observed when the polymorphism was not included (Lanphear BP, et al. Environmental lead exposure during early childhood. Journal of Pediatrics 2002;140:40–47). No significant effect modification of calcium intake on blood lead by genotype was found (p=0.49), therefore intepretation of the results is uncertain. | Fair
| Iron
Lanphear, 2002^195^ | Iron | Prospective cohort study | Children living in Rochester, NY and were 5–7 months old at baseline visit. Low income families. (same participants in Haynes, 2003) | 249 | 2.9 micro-g/dL (95% CI, 2.7–3.1) | Assessed BPbs of children at 6, 12, 18, and 24 months of age. Nutritional intake was also measured at these same timepoints by a trained interviewer asking the caretaker questions about child's dietary intake using a food frequency checklist (Willet, 1990). Breast milk was incorporated into checklist. | At 24 months of age, BPbs were 7.5 micro-g/dL. 82 (33%) had BPb levels ≥ 10 micro-g/dL; 32 (13%) has levels ≥ 15 micro-g/dL; 14 (6%) had levels ≥ 20 micro-g/dL. | ND | In adjusted analysis, lead-contaminated floor dust, soil, and water contributed to lead intake in first 2 years of life (p < 0.05). BPb concentration was > 50% higher in African American children than Caucasian children. | Good/ Fair
| Calcium | | | | | | Dietary iron intake was inversely associated with BPb levels (p = 0.03) during the first year of life. Calcium intake was not associated with BPb concentration.
| Vitamin C
| Vitamin D
Lee, 2005^12^ | Calories | Cross-sectional study | Women 20–49 years old from National Healh and Nutritional Survey (NHANES III) | 4,394 (3,716 had complete data for all variables in study) | NA | NHANES III data retrieved through interviews, questionnaires, and examinations. Survey contained consumption measurements for 1 day (24 hour recall) along with dietary, nutritional, and health status measurements. | Average blood lead level of reproductive age woman was 1.78 micro g/dL. | ND | | NA
| Fat | | | | | | Inverse associations (p<0.05) between blood lead level and thiamine and serum folate. Positive associations (p< 0.05) between blood lead level and iron, pyridoxine intake, and folate.
| Thiamine
| Pyridoxine
| Vitamin E
| Ascorbic acid
| Folate
| Calcium
| Phosphorus
| Iron
Lucas, 1996^188^ | Calories | Cross-sectional study | Children ages 9–6 years, cared for at University of Maryland at Baltimore Pediatric Ambulatory Center. Low income, innercity families. | 296 | NA | Nutritional status (using modified, unvalidated for children, but validated for adults Gladys Block food frequency questionnaire), socioeconomic aspects, medical history, and potential sources of lead exposure were assessed. Blood samples were evaluated for BPbs, serum iron (ferritin), free erythrocyte photoporhyrin, calcium, and hematocrit. | Average blood lead was 11.4 micro g/dL. After adjusting for confounders using multiple linear regression models, significant positive associations with blood lead were found independently for total caloric intake (p=0.01) and dietary fat (p=0.05). | ND | | NA
| Fat
Markowitz, 1996^157^ | Iron | Prospective cohort study | Moderately lead poisoned children referred to Montefiore Medical Lead Clinic from 1986-1992 with BPbs 25–55 micro g/dL. Low income, inner-city families, living in pre-1960 housing. 2/3 Hispanic, 1/3 African American. | 79 | NA | Assessed BPbs repeated over a 6 month time period. Mixed interventions (except chelation because of negative lead mobilization effects to the chelating agent) including iron therapy forr children with ferritin levels < 16 micro g/L. | BPbs declined 27% on average over 6 months. | ND | Mixed interventions. Describes home assessment tool HES (home environmental score). | Fair
| | | | | | | Two thirds < 25 micro g/dL, 7% < 15 micro g/dL.
| | | | | | | However, iron status did not account for change in BPb levels.
Markowitz, 2004^189^ | Calcium | Randomized controlled trial | Children ages 1–6 referred to Montefiore Medical Center with BPbs between 10–44 micro g/dL | 88 | 10–44 micro g/dL | 1800 mg Ca per day between supplement and diet for treatment group. | No significant differences between BPb levels in either group. Ca supplementation of 1800 mg/day for 3 months or 6 months did not reduce BPb levels. | Abdominal pain complaints occurred infrequently in both groups. | BPb boundaries chosen because 10 micro g/dL is current definition of lead poisoning, and BPb ≥ 45 micro g/dL required chelation therapy. | Good/ Fair
| | | | | | Stratified children into 2 groups: 12–35 months and 36–72 months, based on epidemiology of lead absorption. | | | Also measured hand-to-mouth behavior and dust samples also measured.
| | | | | | BPbs measured at enrollment, 3 months, and 6 months.
Sargent, 1999^190^ | Calcium | RCT | Infants aged 3.6 – 6 months in Lawrence, MA. High proportion of low income families. Data collected 1991-1993. Majority Latino (> 90%). | 103; complete lab data collected for 81 (78.6%) of original random assignment | < 25 micro g/dL | Infants randomized to receive iron-fortified infant formula (465 mg Ca and 317 mg P/L) or the same formula with added calcium glycerophosphate (1800 mg Ca and 1390 mg P/L) for 9 months. Infants were assessed monthly for tolerance of formula, adverse effects, and size measurements. Urine samples were analyzed at baseline and 1,2,4,6,9 months to measure excretion of calcium and creatinine. Blood samples were taken at baseline, 4 and 9 months to measure BPbs, serum calcium serum phosphorous, serum ferritin, total iron binding capacity, erythrocyte protoporphyrin, and hematocrit. Dust and water samples were taken at 1 month after randomization. | There was no significant difference between groups in the mean ratio of urinary calcium to creatinine, serum calcium and phosphorus, or change in iron status (serum ferritin, total iron binding capacity). At month 4, the median increase from baseline BPbs in the treatment group was 57% of the increase for the control group (p=0.039), but this effect weakened after month 4 through the final 9th month of the trial. Because the effect did not last, cannot conclude that calcium glycerohosphate supplement prevented lead absorption. | 10 children distributed evenly between groups has at least one urine sample with a ratio of urinary calcium to creatinine above the age-related norm. 2 had repeat elevated levels (one in each group). 1 child in the control group had an elevated serum calcium level.13 children had low serum ferritin concentrations (5 in control and 8 in treatment group). | | Good/ Fair
| Iron
| Phorphorus
Schell, 2004^191^ | Calcium | Prospective cohort study | Mother/Infant pairs of low socioeconomic status in Albany County, NY from APILS (Albany pregnancy infancy lead study) 1992-1998 | 169 | 1.6 – 10 micro g/dL at birth | Diets assessed at 3 month intervals using 24 hour diet recall reported by primary caregiver. Potential impact of protein, iron, zinc, calcium, vitamin D, fat, serum vitamin D, ferrtin at 6 and 12 months of age examined. Nutritional intakes are compared to the 1989 Recommended Dietary Allowances (RDA) amounts. In first 6 months, few were below the RDA amounts for calcium, vitamin D, or iron, but 15.4% fell below for protein, 25% fell below for calories, adn 37.9% fell below for zinc. At 9 and 12 months, > 20% fell below RDAs for calcium, vitamin D, iron, and zinc, and two thirds fell below for vitamin D. | By 6 months, mean BPbs significantly increased from birth to 2.3 micro g/dL (p<0.001); none were ≥ 10 micro g/dL. By 12 months, mean BPbs significantly increased from 6 months to 5.1 micro g/dL (p<0.001) and 18% were ≥ 10 micro g/dL. | ND | | Fair
| Ferritin | | | | | | Observed significant inverse relationships between infant's 6 month lead level and intake of zinc (p= 0.003), iron (p=0.015), and calcium (p<0.001). At 12 months, low iron intake continued to be associated with higher lead levels (p=0.041), although zinc and calcium did not.
| Iron | | | | | | Protein had a paradoxal effect (associated with lower lead at 6 months (p=0.001), but higher lead at 12 months. Serum vitamin D and ferritin were not associated with lead levels, nor was vitamin supplement use.
| Protein
| Supplements
| Vitamin D
| Zinc
Schnell, 2003^192^ | Calcium | Prospective cohort study | Mother/Infant pairs of low socioeconomic status in Albany County, NY from APILS (Albany pregnancy infancy lead study) 1992-1998 | 220 | 1.58 micro g/dL neonates | Maternal BPbs, anthropometry (weight, arm circumference, triceps skinfold thickness, etc.), and diet were assessed in each trimester and compared with BPbs of neonates (cord or venous blood). | Mother's BPbs were strongly and positively related to neonates BPbs (p<0.001). For the anthropometric measures of maternal nutritional status, variables measuring gain in weight and arm circumference were negatively related to neonate BPbs (p<0.001). Dietary intakes in iron (p=0.003) and vitamin D (p=0.038) were negatively related to neonates BPbs. The effects of zinc varied substantially. Calcium was negatively related to BPbs before controlling for age, education index, etc. (p=0.042), but not after controlling for these variables. Serum ferritin, serum vitamin D, and supplements were not significantly related to BPbs of neonates. African American mothers and newborns have significantly higher BPbs than Caucasians (p<0.001), except in the 2nd trimester. | ND | | Fair
| Ferritin | | | | | More than 50% of the mothers had nutritional intakes below the recommended dietary allowances for zinc, calcium, vitamin D, and kilocalories, determined by modified version of National Cancer Institute Food Questionnaire.
| Iron
| Supplements
| Vitamin D
| Zinc
Simon, 1999^193^ | Ascorbic acid | Cross-sectional study | Probability sample of US population from the Third National Health and Nutrition Examination Survey (NHANES III), 1988-1994 without a history of lead poisoning. Adults and youths. | 4,213 youths aged 6–16 and 15, 365 adults aged ≥ 17 | NA | Measured BPbs and serum ascorbic acid levels (by high-performance liquid chromatography). Quantative nutrition data were collected using 24 hour recall. | 22 (0.5%) youths had elevated BPbs. 57 (0.4%) adults had elevated BPbs. Serum ascorbic levels ranged from 0–170 micro mol/L, with the mean for the youths 55 micro mol/L and mean for the adults 43 micro mol/L. | ND | Could not include children age 1–5 years because ascorbic acid levels were not measured in NHANES III. | NA
| | | | | | | After controlling for the effects of age, race, sex, income level, and dietary energy, fat, calcium, iron, and zinc intake, youths in the highest serum ascorbic acid tertile had an 89% decreased prevalence of elevated BPbs compared with youths in the lowest serum ascorbic acid tertile (p=0.002). Adults in the highest 2 serum ascorbic acid tertiles had a 65% to 68% decreased prevalence of elevated BPbs compared with adults in the lowest serum ascorbic acide tertile (p=0.03). As a continuous predictor, serum ascorbic acid level was independently associated with decreased BPbs among adults (p<0.001), but not among youths. | | No relationship observed between dietary ascorbic acid levels and BPbs, only serum ascorbic acid levels.
Zierold, 2004^194^ | Many, not described | Retrospective Cohort Study with comparison | Data from Wisc onsin Childhood Lead Poisoning Prevention Program from 1996-2000. Children ages 0–6. | 111,196 | mean 5.29 micro g/dL | 52,407 children ages 0–6 enrolled in Wisconsin Childhood Lead Poisoning Prevention Program's Special Nutrition Program with venous BPbs measured are compared with 58,789 all other children ages 0–6 with venous BPbs measured in the Wisconsin Prevention Program, but not enrolled in the Special Nutrition Program. | For those in the Special Nutrition Program, mean BPbs declined over the 4 year time period from 7.89 micro g/dL to 5.29 micro g/dL. Average BPb decline of 0.64 micro g/dL per year. | ND | | Fair
| | | | | | | For the comparision group, mean BPbs declined over the 4 year time period from 5.51 micro g/dL to 3.70 micro g/dL. Average BPb decline of 0.42 micro g/dL per year. The difference between the groups was not statistically significant (p=0.25). African American children in the Special Nutrition Program BPbs had a significantly quicker decline compared with Caucasian children (p=0.03).

Abbreviations: BPbs, Blood lead levels; Ca, Calcium; NA, Not applicable; ND, Not described.

Table 5 Summary of Nutritional Interventions on Children's Blood Lead Levels

Studies | Ascorbic Acid | Calcium | Calories | Carbohydrates | Fat | Ferritin | Folate | Folate (serum) | Iron | Multiple, Not Described | Phosphorus | Protein | Pyridoxine | Supplements | Thiamine | Vitamin C | Vitamin D | Zinc
Randomized Controlled Trials
Dalton 1997^185^ | | NS | | | | | | | NS | | NS
Markowitz 2004^189^ | | NS
Sargent 1999^190^ | | NS | | | | | | | NS | | NS
Prospective Cohort Studies
Gallicchio 2002^186^ | | | P | N | P | | | | | | | | | | | N
Haynes, 2003^196^ | | N*
Lanphear, 2002^195^ | | NS | | | | | | | N
Markowitz 1996^157^ | | | | | | | | | NS
Schell 2003^192^ | | NS | | | | NS | | | N | | | | | NS | | | N (dietary) | Varied
| | | | | | | | | | | | | | | | | NS (serum)
Schell 2004^191^ | | NS | | | | NS | | | N | | | Varied | | NS | | | NS (serum) | NS
Retrospective Cohort Study (with comparision group)
Zierold 2004^194^ | | | | | | | | | | NS
Cross Sectional Studies
Hammad 1996^187^ | | | | | | | | | N
Lee, 2005^12^ | | | | | | | P | N | P | | | | P | | N
Lucas 1996^188^ | | | P | | P
Simon 1999^193^ | N

Abbreviations: P, positive relationship: N, negative/inverse relationship; NS, not significant/no relationship

* Calcium intake was inversely associated with children's blood lead (p=0.03) in a multivariate model that included VDR Fok 1 genotype as an independent variable. No significant effect modification of calcium intake on blood lead by genotype was found (p=0.49). No significant association was observed when the polymorphism was not included (Lanphear, 2002).

Three RCTs^185,^ ^189,^ ^190^ and three prospective cohort studies^191,^ ^192,^ ^195^ did not find a significant correlation between calcium and blood lead levels, although one prospective cohort study ^196^ found an inverse association. Fat and caloric intakes were positively associated with blood levels in a prospective cohort study^186^ and a cross-sectional study.^188^ Carbohydrates had an inverse association according to a prospective cohort study.^186^ Two prospective cohort studies^191,^ ^192^ found that ferritin is not significantly related to blood lead levels. One cross-sectional study^12^ found a positive association with folate and a negative association with serum folate. Iron has not been shown to have a effect on blood lead levels in two RCTs^185,^ ^190^ and one prospective cohort study,^157^ although three prospective cohort studies^191,^ ^192,^ ^195^ and one cross-sectional study^187^ reveal a negative association, while one cross-sectional study shows a positive association.^12^ Two RCTs^185,^ ^190^ found no correlation between blood lead levels and phosphorus. One cross-sectional study found a positive association between blood lead levels and pyridoxine.^12^ Protein had a paradoxical effect in one prospective cohort study, significantly associating with low lead levels at 6 months, but then higher lead levels at 12 months.^191^ Two prospective cohort studies showed no relationship between supplement use and blood lead levels.^191,^ ^192^ One cross-sectional study found a negative association between blood lead levels and thiamine.^12^ Vitamin C is inversely related with blood lead levels according to a prospective cohort study.^186^ Vitamin C has also been inversely associated with blood lead levels in a cross-sectional study,^193^ Dietary vitamin D is also inversely related to blood lead levels according to a prospective cohort study,^192^ whereas serum vitamin D has not been correlated with blood lead levels in two prospective cohort studies.^191,^ ^192^ Two prospective cohort studies yielded different results concerning zinc, showing no association to blood lead levels,^191^ and conflicting results.^192^

Despite the significant relationships between nutrients and children's blood lead levels in the epidemiological studies described above, it is noticeable that none of the RCTs found significant correlations.^185,^ ^189,^ ^190^ Similarly, a 2004 retrospective cohort study, using data from the Wisconsin Childhood Lead Poisoning Prevention Program in children aged 0–6, compared blood levels of children enrolled in the Special Supplemental Nutrition Program for Women, Infants, and Children from 1996 to 2000 with blood levels of children not enrolled in the nutrition program, and did not find any significant differences between the two groups.^194^ Other cohort studies reveal significant association with calories, carbohydrates, fat, iron, vitamin C and vitamin D,^157,^ ^186,^ ^191,^ ^192,^ ^195,^ ^196^ whereas the cross-sectional studies demonstrate significant associations with ascorbic acid, calories, fat, folate, serum folate, iron, pyridoxine, and thiamine.^12,^ ^187,^ ^188,^ ^193^ Adverse effects were reported in two of the fourteen studies; both are RCTs. A calcium study using a 1800 mg/d^189^ dosage reported abdominal pain in both the treatment and control groups. A calcium glycerophosphate-supplemented infant formula study reported elevated ratios of urinary calcium to creatinine and low concentrations of serum ferritin, but these effects also occurred in both the treatment and placebo groups.^190^ None of the other studies reported adverse effects.

A recent review concluded that experimental studies in animals and observational studies of humans provide evidence that calcium supplementation during the second half of pregnancy may reduce prenatal lead exposure by reducing mobilization of lead from bone.^197^

## Key Questions 4 and 6: Adverse Effects of Screening and Intervention

The most common adverse effects of screening for elevated lead levels are false-positive fingerstick results, and the anxiety, inconvenience, work or school absenteeism, and financial costs associated with return visits and repeat tests. An EDTA lead mobilization test, used for some children with blood lead levels of 30–44 micro-g/dL,^198^ requires intramuscular or intravenous infusion, a stay at the clinical center for at least 8 hours, and for young children, application of urine collection bags.^199^ Residential lead-based paint and dust hazard control, when improperly done,^23^ may produce acute increases in blood lead levels in resident children and abatement workers, occasionally necessitating hospitalization and chelation therapy.^200^–^204^ Currently recommended techniques for lead hazard reduction are likely to reduce these adverse effects.^23^ Chelating agents for asymptomatic lead poisoning have also been associated with important adverse effects. EDTA and dimercaprol (BAL) have transient renal, hepatic, and other toxicity, require intravenous or intramuscular injection, and generally require hospitalization for administration.^124,^ ^205,^ ^206^ Common adverse effects of d-penicillamine are penicillin-like sensitivity reactions and transient nephrotoxicity which may be dose-related ^207^; there are rare life-threatening reactions.^124,^ ^134,^ ^147,^ ^156^ Adverse effects of succimer (meso-2,3-dimercaptosuccinic acid, or DMSA) include mild gastrointestinal (vomiting and diarrhea) and systemic symptoms, rashes, transient hyperphosphatasemia, neutropenia, eosinophilia and elevations in serum transaminases, in up to 10% of cases.^137^–^140,^ ^144^–^146,^ ^148,^ ^208^