# Methods for Updating the 1996 Report^1^

## Problem Formulation

Members of the USPSTF defined the scope of this update, in cooperation with the Agency for Healthcare Research and quality (AHRQ) and the Oregon Evidence Based Practice Center (EPC) personnel. The Task Force's goals for this update were to address the gaps in the literature revealed in the 1996 USPSTF recommendations.^2^ These gaps related to the accuracy of risk assessment questionnaires in children with varying blood lead levels, the population prevalence at which to change from targeted screening to universal screening, the effectiveness of interventions to lower lead levels, and cost-effectiveness analyses of lead screening programs.

## Search for New Studies

EPC personnel searched MEDLINE, reference lists of review articles, and tables of contents of leading pediatric journals for studies published in 1995 or later that contained new information about the prevalence, diagnosis, natural course, or treatment of elevated lead levels in asymptomatic children ages 1–5 and in pregnant women. Articles that met the following criteria were included in this update:

1) The study was an original meta-analysis, prospective cohort study, controlled trial, quasi-experimental study with concurrent controls, or case-control study; not a case series, case report, or comparison with historical controls.
2) The study was not included in the 1996 review.
3) The study was rated at least “fair-quality” using the USPSTF criteria (Appendix 1) for internal validity.

## Synthesis

This report uses text and format from the 1996 report^1^ on lead screening, updating the text and citations where appropriate. Members of the USPSTF and AHRQ identified critical issues for updating the 1996 USPSTF guidelines for lead screening. To prepare this update, we reviewed trials and epidemiologic studies published since January 1995 bearing on these critical issues. For the critical key questions only (see below), we used standard USPSTF methods^3^ to abstract information about the design, results, and internal validity of each study, and included only those studies we rated fair-quality or better. We reviewed the populations of asymptomatic children and pregnant women separately.

Key questions in the 2005 work assignment for CHILDREN were stated as follows:

- KQ1: Is there direct evidence that screening for lead results in improved health outcomes (i.e. cognitive changes, behavioral problems, learning disorders)?
- KQ2: What is the prevalence of elevated lead in children? Are there population-level risk factors that identify children at higher risk for elevated lead levels (i.e., geography, race/ethnicity, socioeconomic status, age)?
- KQ 3: Can screening tests accurately detect elevated blood lead levels? What is the accuracy of using questionnaires (or other tools) for risk factor assessment at various blood lead levels? What is the optimal frequency for screening? What is the optimal frequency for repeat testing?
- KQ4: What are the adverse effects of screening?
- KQ5: Do interventions (i.e. counseling families to reduce lead exposure, nutritional interventions, residential lead hazard control techniques, chelation therapy) for elevated lead levels result in improved health outcomes?
- KQ6: What are the adverse effects of interventions?
- KQ7: What are cost effectiveness issues?

Members of the USPSTF and AHRQ identified KQs 1 and 5 as critical key questions. We therefore updated KQs 1 and 5 using standard systematic review procedures. We conducted a selected review of the literature that addressed KQs 2–4, 6, and 7.

Key questions in the 2005 work assignment for PREGNANT WOMEN were stated as follows:

- KQ1: Is there direct evidence that screening in asymptomatic pregnant women for lead results in improved health outcomes (i.e., cognitive changes in offspring, perinatal outcomes including birth weight/preterm delivery etc, maternal blood pressure)?
- KQ2: What is the prevalence of elevated lead in asymptomatic pregnant women? Are there population-level risk factors that identify pregnant women at higher risk for elevated lead levels (i.e., geography, racial/ethnicity, socioeconomic status, age)?
- KQ3: Can screening tests accurately detect elevated blood lead levels? What is the accuracy of using questionnaires (or other tools) for risk factor assessment at various blood lead levels?
- KQ4: What are the adverse effects of screening?
- KQ5: Do interventions (i.e., counseling families to reduce lead exposure, nutritional interventions, residential lead hazard control techniques, chelation therapy) for elevated lead levels result in improved health outcomes?
- KQ6: What are the adverse effects of the interventions?
- KQ7: What are cost effectiveness issues?

We used standard systematic review procedures to address KQs 1 and 5. We conducted a selected review of the literature on pregnant women for KQs 2–4, 6, and 7.

New studies or information for key questions for children and pregnant women are discussed throughout the text below using the format from the 1996 chapter for this topic.