# Appendixes

Appendix A

Appendix B USPSTF Hierarchy of research design and quality rating criteria.

Appendix C

Appendix D Additional study detail for key question 2

Appendix E