# Appendix E

Appendix E Table 1 Studies of high-risk groups for C282Y homozygosity or HH

## Table 2. Studies excluded from key question 3

### Study Citation Reason for exclusion

Adams PC, Agnew S. Alcoholism in hereditary hemochromatosis revisited: prevalence and clinical consequences among homozygous siblings. Hepatology. 1996;23(4):724-7. Case series. [pmid: 8666324].
Adams PC, Kertesz AE, Valberg LS. Clinical presentation of hemochromatosis: a changing scene. American Journal of Medicine. 1991;90(4):445-9. Case series. [pmid: 2012084].
Adams PC, Kertesz AE, Valberg LS. Screening for hemochromatosis in children of homozygotes: prevalence and cost-effectiveness. Hepatology. 1995;22(6):1720-7. <18 yrs included. [pmid: 7489980].
Adams PC. Haemochromatosis: find them or forget about them?. European Journal of Gastroenterology & Hepatology. 2004;16(9):857-8. Editorial. [pmid: 15316408].
Assy N, Adams PC. Predictive value of family history in diagnosis of hereditary hemochromatosis. Digestive Diseases & Sciences. 1997;42(6):1312-5. No HFE testing. [pmid: 9201100].
Bacon BR, Olynyk JK, Brunt EM, Britton RS, Wolff RK. HFE genotype in patients with hemochromatosis and other liver diseases. Annals of Internal Medicine. 1999;130(12):953-62. Does not meet our definition of clinical hemochromatosis. [pmid: 10383365].
Bassett ML, Halliday JW, Ferris RA, Powell LW. Diagnosis of hemochromatosis in young subjects: predictive accuracy of biochemical screening tests. Gastroenterology. 1984;87(3):628-33. Does not include primary results. [pmid: 6745616].
Bassett ML, Halliday JW, Powell LW. Value of hepatic iron measurements in early hemochromatosis and determination of the critical iron level associated with fibrosis. Hepatology. 1986;6(1):24-9. Feb. Case series. [pmid: 3943787].
Bhavnani M, Lloyd D, Bhattacharyya A, Marples J, Elton P, Worwood M. Screening for genetic haemochromatosis in blood samples with raised alanine aminotransferase. Gut. 2000;46(5):707-10. Quality. [pmid: 10764716].
Bonkovsky HL, Jawaid Q, Tortorelli K, LeClair P, Cobb J, Lambrecht RW, et al. Non-alcoholic steatohepatitis and iron: increased prevalence of mutations of the HFE gene in non-alcoholic steatohepatitis. Journal of Hepatology. 1999;31(3):421-9. Does not meet our definition of clinical hemochromatosis. [pmid: 10488699].
Bregman H, Gelfand MC, Winchester JF, Manz HJ, Knepshield JH, Schreiner GE. iron-overload-associated myopathy in patients on maintenance haemodialysis: a histocompatibility-linked disorder. Lancet. 1980;2(8200):882-5. Not the correction population. [pmid: 6107546].
Brissot P, Moirand R, Jouanolle AM, Guyader D, Le Gall JY, Deugnier Y, David V. A genotypic study of 217 unrelated probands diagnosed as “genetic hemochromatosis” on “classical” phenotypic criteria. Journal of Hepatology. 1999;30(4):588-93. Does not report relevant prevelance or risk measures. [pmid: 10207799].
Campo S, Restuccia T, Villari D, Raffa G, Cucinotta D, Squadrito G, Pollicino T, Raimondo G. Analysis of haemochromatosis gene mutations in a population from the Mediterranean Basin. Liver. 2001;21(4):233-6. Not the correction population. [pmid: 11454185].
Cavanaugh JA, Wilson SR, Bassett ML. Genetic testing for HFE hemochromatosis in Australia: the value of testing relatives of simple heterozygotes. Journal of Gastroenterology & Hepatology. 2002;17(7):800-3. Does not include primary results. [pmid: 12121511].
Conte D, Manachino D, Colli A, Guala A, Aimo G, Andreoletti M, Corsetti M, Fraquelli M. Prevalence of genetic hemochromatosis in a cohort of Italian patients with diabetes mellitus. Annals of Internal Medicine. 1998;128(5):370-3. Not the correction population. [pmid: 9490597].
Dalury DF, Ewald FC, Christie MJ, Scott RD. Total knee arthroplasty in a group of patients less than 45 years of age. Journal of Arthroplasty. 1995;10(5):598-602. Does not report relevant prevelance or risk measures. [pmid: 9273369].
Ellervik C, Mandrup-Poulsen T, Nordestgaard BG, Larsen LE, Appleyard M, Frandsen M, et al. Prevalence of hereditary haemochromatosis in late-onset type 1 diabetes mellitus: a retrospective study. Lancet. 2001;358(9291):1405-9. Not the correction population. [pmid: 11705485].
Feller ER, Pont A, Wands JR, Carter EA, Foster G, Kourides IA, et al. Familial hemochromatosis. Physiologic studies in the precirrhotic stage of the disease. New England Journal of Medicine. 1977;296(25):1422-6. Case series. [pmid: 194151].
Fiel MI, Schiano TD, Bodenheimer HC, Thung SN, King TW, Varma CR, et al. Hereditary hemochromatosis in liver transplantation. Liver Transplantation & Surgery. 1999;5(1):50-6. Does not report relevant prevelance or risk measures. [pmid: 9873093].
Gleeson F, Ryan E, Barrett S, Crowe J. Clinical expression of haemochromatosis in Irish C282Y homozygotes identified through family screening. European Journal of Gastroenterology & Hepatology. 2004;16(9):859-63. Does not report relevant prevelance or risk measures. [pmid: 15316409].
Guyader D, Jacquelinet C, Moirand R, Turlin B, Mendler MH, Chaperon J, et al. Noninvasive prediction of fibrosis in C282Y homozygous hemochromatosis. Gastroenterology. 1998;115(4):929-936. Not the correction population. [pmid: 9753496].
Hultcrantz R, Gabrielsson N. Patients with persistent elevation of aminotransferases: investigation with ultrasonography, radionuclide imaging and liver biopsy. Journal of Internal Medicine. 1993;233(1):7-12. Not relevant outcomes. [pmid: 8429291].
Jeffrey GP, Adams PC. Pitfalls in the genetic diagnosis of hereditary hemochromatosis. Genetic Testing. 2000;4(2):143-6. Editorial. [pmid: 10953953].
Jordan JM. Arthritis in hemochromatosis or iron storage disease. Current Opinion in Rheumatology. 2004;16(1):62-6. Review article. [pmid: 14673391].
Jorquera F, Dominguez A, Diaz-Golpe V, Espinel J, Munoz F, Herrera A, et al. C282Y and H63D mutations of the haemochromatosis gene in patients with iron overload. Revista Espanola de Enfermedades Digestivas. 2001;93(5):293-302. Does not report relevant prevelance or risk measures. [pmid: 11488107].
Koefoed P, Dalhoff K, Dissing J, Kramer I, Milman N, Pedersen P, Simonsen K, Tygstrup N, Nielsen FC. HFE mutations and hemochromatosis in Danish patients admitted for HFE genotyping. Scandinavian Journal of Clinical & Laboratory Investigation. 2002;62(7):527-35. Quality. [pmid: 12512743].
Krawczak M, Cooper DN, Schmidtke J. Estimating the efficacy and efficiency of cascade genetic screening. American Journal of Human Genetics. 2001;69(2):361-70. Does not include primary results. [pmid: 11431707].
Li J, Zhu Y, Singal DP. HFE gene mutations in patients with rheumatoid arthritis. Journal of Rheumatology. 2000;27(9):2074-7. Quality. [pmid: 10990216].
Mathews JL, Williams HJ, Williams HJ. Arthritis in hereditary hemochromatosis. Arthritis & Rheumatism. 1987;30(10):1137-41. Not HFE. [pmid: 3675659].
Nassar BA, Zayed EM, Title LM, O'Neill BJ, Bata IR, Kirkland SA, Dunn J, Dempsey GI, Tan MH, Johnstone DE. Relation of HFE gene mutations, high iron stores and early onset coronary artery disease. Canadian Journal of Cardiology. 1998;14(2):215-20. Quality. [pmid: 9520858].
Nelson RL, Persky V, Davis F, Becker E. Risk of disease in siblings of patients with hereditary hemochromatosis. Digestion. 2001;64(2):120-4. Quality. [pmid: 11684826].
Olynyk J, Hall P, Ahern M, Kwiatek R, Mackinnon M. Screening for genetic haemochromatosis in a rheumatology clinic. Australian & New Zealand Journal of Medicine. 1994;24(1):22-5. Quality. [pmid: 8002853].
Panajotopoulos N, Piperno A, Conte D, Mandelli C, Cesana M, Mercuriali F, Fiorelli G, Bianchi PA, Fargion D. HLA typing in 67 Italian patients with idiopathic hemochromatosis and their relatives. Tissue Antigens. 1989;33(4):431-6. Not the correction population. [pmid: 2734773].
Peterlin B, Globocnik PM, Makuc J, Hawlina M, Petrovic D. A hemochromatosis-causing mutation C282Y is a risk factor for proliferative diabetic retinopathy in Caucasians with type 2 diabetes. Journal of Human Genetics. 2003;48(12):646-9. Not the correction population. [pmid: 14618419].
Piperno A, D'Alba R, Fargion S, Roffi L, Sampietro M, Parma S, et al. Liver iron concentration in chronic viral hepatitis: a study of 98 patients. European Journal of Gastroenterology & Hepatology. 1995;7(12):1203-8. Not the correction population. [pmid: 8789313].
Rasmussen ML, Folsom AR, Catellier DJ, Tsai MY, Garg U, Eckfeldt JH. A prospective study of coronary heart disease and the hemochromatosis gene (HFE) C282Y mutation: the Atherosclerosis Risk in Communities (ARIC) study. Atherosclerosis. 2001;154(3):739-46. Does not report relevant prevelance or risk measures. [pmid: 11257277].
Roberts AG, Whatley SD, Morgan RR, Worwood M, Elder GH. Increased frequency of the haemochromatosis Cys282Tyr mutation in sporadic porphyria cutanea tarda. Lancet. 1997;349(9048):321-3. Does not meet our definition of clinical hemochromatosis. [pmid: 9024376].
Sampietro M, Piperno A, Lupica L, Arosio C, Vergani A, Corbetta N, et al. High prevalence of the His63Asp HFE mutation in Italian patients with porphyria cutanea tarda. Hepatology. 1998;27(1):181-4. Does not meet our definition of clinical hemochromatosis. [pmid: 9425935].
Schmid H, Struppler C, Braun GS, Kellner W, Kellner H. Ankle and hindfoot arthropathy in hereditary hemochromatosis. Journal of Rheumatology. 2003;30(1):196-9. Not the correction population. [pmid: 12508413].
Sham RL, Raubertas RF, Braggins C, Cappuccio J, Gallagher M, Phatak PD. Asymptomatic hemochromatosis subjects: genotypic and phenotypic profiles. Blood. 2000;96(12):3707-11. Not the correction population. [pmid: 11090050].
Shoaf EH Jr. Hemochromatosis discovered through blood donor screening for alanine aminotransferase. North Carolina Medical Journal. 1990;51(9):443-5. Case report. [pmid: 2234109].
Siezenga MA, Rasp E, Wijermans PW. Testing families with HFE-related hereditary haemochromatosis. Netherlands Journal of Medicine. 2004;62(5):156-9. Case report. [pmid: 15366698].
Simon M, Alexandre JL, Bourel M, Le Marec B, Scordia C. Heredity of idiopathic haemochromatosis: a study of 106 families. Clinical Genetics. 1977;11(5):327-41. Quality. [pmid: 862210].
Tannapfel A, Stolzel U, Kostler E, Melz S, Richter M, Keim V, et al. C282Y and H63D mutation of the hemochromatosis gene in German porphyria cutanea tarda patients. Virchows Archiv. 2001;439(1):1-5. Does not meet our definition of clinical hemochromatosis. [pmid: 11499833].
Timms AE, Sathananthan R, Bradbury L, Athanasou NA, Wordsworth BP, Brown MA. Genetic testing for haemochromatosis in patients with chondrocalcinosis. Annals of the Rheumatic Diseases. 2002;61(8):745-7. Quality. [pmid: 12117686].